# Scientific Evidence

## Epidemiology and Clinical Consequences

Hypertension is usually defined in adults as a SBP of 140 mm Hg or higher, or a DBP of 90 mm Hg or higher.^3^ Data from the Third National Health and Nutrition Survey (NHANES III) suggest that an estimated 43 million American adults older than 25 have hypertension and that it is more common in African Americans and the elderly than in other groups. In the United States, hypertension is responsible for 35 percent of all myocardial infarctions and strokes, 49 percent of all episodes of heart failure, and 24 percent of all premature deaths.^4^ Additional complications of hypertension include end‐stage renal disease, retinopathy, and aortic aneurysm.^4^‐^6^

In 1998, an estimated $109 billion was spent on the health care of patients with hypertension and its complications; $22 billion of this total was spent on the treatment of hypertension alone.^7^

Hypertension in children has been defined as blood pressure levels that are above the 95th percentile based on age, sex, and height‐specific values derived from large cohort studies of children.^8^ No studies have examined the association between elevated blood pressure in children and adolescents and the future risk for cardiovascular events. Prospective cohort studies have shown that, compared with children who have normal blood pressure, children who have hypertension are more likely to have high blood pressure as young adults.^9^,^10^

Among children with hypertension, the prevalence of secondary hypertension is estimated to be 28 percent compared with a prevalence of 1 percent to 5 percent in adults.^11^ However, there are limited good data on the prevalence or incidence of treatable secondary causes of hypertension among children and adults in the primary care setting, and there are no population‐level data available to estimate the true incidence or prevalence of secondary hypertension in adults or children.

## Accuracy and Reliability of Screening Tests

Office blood pressure measurement (using an appropriate upper arm cuff with either mercury, calibrated aneroid, or validated electronic sphygmomanometer) is the standard screening test for hypertension. When performed correctly, sphygmomanometry provides a measure of blood pressure that is highly correlated with intra‐arterial measurement and highly predictive of cardiovascular risk.^12^ However, office blood pressure measurements exhibit great variability and may not represent the patient's usual blood pressure outside the clinical setting.

Ambulatory blood pressure monitoring provides a measure of average blood pressure over 24 hours as opposed to the isolated values obtained in office checks. Two recent reviews of good‐quality cohort studies found that ambulatory blood pressure measurements correlate better with left ventricular mass and cardiovascular disease than do office blood pressure measurements.^13^ ^,^ ^14^ Ambulatory blood pressure measurement was found to be a better predictor of clinical cardiovascular outcome than clinic‐based approaches.^15^‐^17^ Another review found blood pressure measurements obtained through ambulatory devices more closely predictive of risk for target end organ damage than self‐ or office blood pressure measurements.^18^

Due to the limitations in the reliability of blood pressure measurements, experts commonly recommend that clinicians diagnose hypertension only after obtaining 2 or more elevated readings at 2 or more office visits at intervals of 1 to several weeks.^3^,^13^

## Effectiveness of Early Treatment

Although no studies have examined the direct effect of screening for elevated blood pressure on clinical outcomes, many trials have demonstrated a beneficial effect of treating patients who were enrolled on the basis of elevated blood pressures detected during screening examinations. The risks associated with elevated blood pressure and the potential benefits of screening and subsequent treatment depend both on the degree of blood pressure elevation and on the presence of other cardiovascular risk factors, such as age, sex, lipid disorders, smoking, and diabetes. Although the benefits of treatment generally correlate with achieving a decrease in blood pressure, recent trials suggest the degree of blood pressure reduction is not always a valid intermediate endpoint for predicting the benefits of treatment. One study showed that the 50 percent reduction in heart failure among patients receiving chlorthalidone compared with doxazosin could not be explained by the 2 mm Hg to 3 mm Hg difference in SBP between the 2 agents.^19^

Evidence is emerging that antihypertensive agents differ in efficacy in reducing future cardiovascular events. For example, one trial has shown that, for high‐risk hypertensive patients, chlorthalidone (a diuretic) may be superior to amlodipine (a calcium‐channel blocker) or lisinopril (an angiotensin‐converting enzyme inhibitor).^20^

Several trials that examined the effectiveness of antihypertensive medications in adults with severe (Stage 3) hypertension suggest that treatment reduces the odds of congestive heart failure by 86 percent.^21^ Among patients with mild to moderate elevations in blood pressure (Stages 1 and 2), treatment resulted in reduced rates of stroke among adults younger than 60. Patients older than 60 achieved further reductions in total mortality, including reductions in CVD death, stroke, coronary artery disease events, and congestive heart failure. A systematic review of 8 trials that examined the effects of treating isolated systolic hypertension in the elderly found that active treatment reduced both stroke and coronary heart disease events by 30 percent, CVD by 18 percent, and total mortality by 13 percent.^22^ The number needed to treat over 5 years to prevent 1 cardiovascular event was 18 for men and 38 for women.

The relative benefit of treating high blood pressure appears similar across different levels of cardiovascular risk. As a result, individuals with higher absolute risk for experiencing future adverse cardiovascular events because of other coexisting risk factors experience greater absolute benefit from blood pressure reduction than those at lower risk for future adverse cardiovascular events. This benefit appears to hold true across all age groups and for reduction in both systolic and diastolic blood pressure.

The effect of more aggressive blood pressure treatment goals in patients within the general population has not been well studied. Patients with diabetes appear to derive additional benefit when blood pressure treatment goals are set below 140/90 mm Hg. In the United Kingdom Prospective Diabetes Study (UKPDS), patients with diabetes who were randomized to more aggressive blood pressure reduction (mean blood pressure of 144/82 mm Hg) were found to reduce the number of events of any diabetes‐related clinical endpoint by 24 percent and to reduce diabetes‐related deaths by 32 percent, compared with patients in the less aggressive reduction arm (mean blood pressure of 154/87).^23^ Similar effects were observed in the Hypertension Optimal Treatment (HOT) Trial, which showed that more aggressive treatment of blood pressure in diabetic patients reduced major cardiovascular events by 49 percent.^24^ The few trials that have examined the effect of aggressive blood pressure reduction in patients with renal insufficiency or renal failure found mixed results.

No studies have examined the effects of nonpharmacological therapies (e.g., weight reduction, increased physical activity, sodium reduction, potassium supplementation, decreased alcohol intake, and stress management) on CVD events. A number of short‐term randomized controlled trials (RCTs), however, have studied the effects of nonpharmocological therapies on blood pressure. A systematic review found that interventions to promote weight loss lowered blood pressure.^25^ Evidence has also shown moderate physical activity to be more effective than vigorous activity in reducing SBP.^26^ Several studies have demonstrated that reducing dietary sodium intake lowers blood pressure among people with hypertension.^27^ ^,^ ^28^ In a systematic review of the effect of oral potassium supplementation on blood pressure, potassium supplementation (60 mmol or more) was estimated to lower SBP by 3.1 mm Hg and DBP by 2.0 mm Hg.^29^ Among patients whose alcohol consumption is high (20 to 40 standard drinks per week), reducing alcohol consumption by at least 50 percent produced a 3.3 mm Hg reduction in SBP and 2.0 mm Hg reduction in DBP.^30^ Evidence on the effects of stress management suggests stress reduction/relaxation and cognitive therapy‐based interventions lower blood pressure. However, the actual benefit of stress management remains unclear because many of the trials included in the review were of only fair quality. Evidence is insufficient to determine the combined impact of multiple, simultaneous nonpharmacological interventions.

While no RCTs have examined the effects of pharmacological interventions on blood pressure in children, several uncontrolled short‐term trials found that various agents could decrease blood pressure over several days to 4 weeks. No longer‐term studies of the effects of medications in children are available. Few studies have evaluated the effects of nonpharmacological interventions in reducing elevated blood pressure in children.

## Potential Harms of Screening and Treatment

Initially, some studies suggested that screening and labeling individuals with hypertension may result in adverse psychological effects and transient increases in absenteeism.^31^‐^36^ However, studies that have measured psychological well‐being have found inconsistent effects of screening and diagnosis. Several cohort studies showed mixed effects on rates of absenteeism, and the causes of absenteeism were not well established.^36^ ^,^ ^37^ In children, too few studies have examined the potential harms of screening to draw conclusions.

Potential adverse effects of drugs—some sufficiently bothersome to interfere with adherence to the medication regimen—are common, but serious adverse drug reactions are rare. Physicians should take adverse effects into consideration when deciding whether to treat and which treatment to use.