# Summary of Recommendations

- The U.S. Preventive Services Task Force (USPSTF) concludes that the evidence is insufficient to recommend for or against routinely screening high-risk pregnant women for bacterial vaginosis (BV). (See Clinical Considerations for discussion of populations at high risk.) (I recommendation). The USPSTF found good-quality studies with conflicting results that screening and treatment of asymptomatic BV in high-risk pregnant women reduces the incidence of preterm delivery. The magnitude of benefit exceeded risk in several studies, but the single largest study reported no benefit among high-risk pregnant women.
- The USPSTF recommends against routinely screening average-risk asymptomatic pregnant women for BV. (D recommendation). There is good evidence that screening and treatment of BV in asymptomatic women who are not at high risk does not improve outcomes such as preterm labor or preterm birth.