# References

1 U.S. Preventive Services Task Force. Screening for gestational diabetes. In: Guide to Clinical Preventive Services, 2nd ed. Washington, DC: Office of Disease Prevention and Health Promotion; 1996:193‐208.
2 Brody SC, Harris RP, Lohr KN. Screening for gestational diabetes: A summary of the evidence for the U.S. Preventive Services Task Force. Obstet Gynecol. 2003;101:380-92. [pmid: 12576264].
3 Brody SC, Harris R, Whitener BL, et al. Screening for Gestational Diabetes. Systematic Evidence Review No. 26 (Prepared by RTI‐University of North Carolina at Chapel Hill Evidence‐Based Practice Center under Contract No. 290‐97‐011). Rockville, MD: Agency for Healthcare Research and Quality. May 2002. (Available on AHRQ Web site at: www.ahrq.gov/clinic/serfiles.htm).
4 WHO Consultation: Definition, diagnosis and classification of diabetes mellitus and its complications: report of a WHO Consultation. Part 1: diagnosis and classification of diabetes mellitus. Geneva, WHO/NCD/NCS/99.2, World Health Org., 1999.
5 American Diabetes Association. Gestational diabetes mellitus Diabetes Care 2002 25(Suppl 1) S94 6
6 American College of Obstetricians and Gynecologists Practice Bulletin. Clinical management guidelines for obstetrician‐gynecologists. Number 30, September 2001 Obstet Gynecol 2001 98 3 525 38 11547793
7 Magee M, Walden C, Benedetti T, Knopp R. Influence of diagnostic criteria on the incidence of gestational diabetes and perinatal morbidity. JAMA. 1993;269(5):609-15. [pmid: 8421365].
8 Solomon C, Willet W, Carey V, et al. A prospective study of pregravid determinants of gestational diabetes mellitus. JAMA. 1997;278(13):1078-83. [pmid: 9315766].
9 Moses R, Moses J, Davis W. Gestational diabetes: do lean young Caucasian women need to be tested?. Diabetes Care. 1998;21(11):1803-6. [pmid: 9802724].
10 Lavin JP, Barden TP, Miodovnik M. Clinical experience with a screening program for gestational diabetes. Am J Obstet Gynecol. 1981;141(5):491-4. [pmid: 7294074].
11 Marquette G, Klein V, Niebyl J. Efficacy of screening for gestational diabetes. Am J Perinatol. 1985;2(1):7-9. [pmid: 3921038].
12 Lemen PM, Wington TR, Miller‐McCarthy AJ, Cruikshank DW. Screening for gestational diabetes mellitus in adolescent pregnancies. Am J Obstet Gynecol. 1998;178(6):1251-6. [pmid: 9662309].
13 Southwick RD, Wigton TR. Screening for gestational diabetes mellitus in adolescent Hispanic Americans. J Reprod Med. 2000;45(1):31-4. [pmid: 10664944].
14 Harlass F, Brady K, Read J. Reproducibility of the oral glucose tolerance test in pregnancy. Am J Obstet Gynecol. 1991;164:564-8. [pmid: 1992702].
15. Mondalou H, Dorchester W, Thorosian A, Freeman R. Macrosomia—maternal, fetal, and neonatal implications. Obstet Gynecol. 1980;55(4):420-4. [pmid: 7366896].
16 Spellacy W, Miller S, Winegar A, Peterson P. Macrosomia—maternal characteristics and infant complications. Obstet Gynecol. 1985;66:158-61. [pmid: 4022478].
17 Berard J, Dufour P, Vinatier D, et al. Fetal macrosomia: risk factors and outcome. A study of the outcome concerning 100 cases >4500 g. Eur J Obstet Gynecol Reprod Biol. 1998;77(1):51-9. [pmid: 9550201].
18 Menticoglou S, Manning F, Morrison I, Harman C. Must macrosomic fetuses be delivered by cesarean section? A review of outcome for 786 babies greater than or equal to 4,500 grams. Aust N Z J Obstet Gynaecol. 1992;32(2):100-3. [pmid: 1520190].
19. Rouse D, Owen J. Prophylactic cesarean delivery for fetal macrosomia diagnosed by means of ultrasonography—A Faustian bargain?. Am J Obstet Gynecol. 1999;181(2):332-8. [pmid: 10454678].
20 Lazer S, Biale Y, Mazor M, Lewenthal H, Insler V. Complications associated with the macrosomic fetus. J Reprod Med. 1986;31:501-5. [pmid: 3735262].
21 Lipscomb K, Gregory K, Shaw K. The outcome of macrosomic infants weighing at least 4500 grams: Los Angeles County + University of Southern California experience. Obstet Gynecol. 1995;85(4):558-64. [pmid: 7898833].
22 el Madany A, Jallad K, Radi F, el Hamdan H, O'deh H. Shoulder dystocia: anticipation and outcome. Int J Gynaecol Obstet. 1990;34:7-12. [pmid: 1671025].
23 Morrison J, Sanders J, Magann E, Wiser W. The diagnosis and management of dystocia of the shoulder. Surg Gynecol Obstet. 1992;175(6):515-22. [pmid: 1448731].
24 Hardy A. Birth injuries of the brachial plexus: incidence and prognosis. J Bone Joint Surg Br 1981;63‐B:98‐101.
25 American College of Obstetricians and Gynecologists. Diabetes and pregnancy. Washington, DC. American College of Obstetricians and Gynecologists. Technical Bulletin No. 200, 1994.
26 Gross T, Sokol R, Williams T, Thompson K. Shoulder dystocia: a fetal‐physician risk. Am J Obstet Gynecol. 1987;156(6):1408-18. [pmid: 3591856].
27 McFarland L, Raskin M, Daling J, Benedetti T. Erb/Duchenne's palsy: a consequence of fetal macrosomia and method of delivery. Obstet Gynecol. 1986;68(6):784-8. [pmid: 3785790].
28 Sandmire H, O'Halloin T. Shoulder dystocia: its incidence and associated risk factors. Int J Gynaecol Obstet. 1988;26:65-73. [pmid: 2892741].
29 Okun N, Verma A, Mitchell B, Flowerdew G. Relative importance of maternal constitutional factors and glucose intolerance of pregnancy in the development of newborn macrosomia. J Matern Fetal Med. 1997;6(5):285-90. [pmid: 9360188].
30 Lucas M, Lowe T, Bowe L, McIntire D. Class A1 gestational diabetes: A meaningful diagnosis?. Obstet Gynecol. 1993;82(2):260-65. [pmid: 8336875].
31 Naylor C, Sermer M, Chen E, Sykora K. Cesarean delivery in relation to birth weight and gestational glucose tolerance: pathophysiology or practice style? Toronto Tri‐Hospital Gestational Diabetes Investigators. JAMA. 1996;275(15):1165-70. [pmid: 8609683].
32 Metzger B, Coustan D. Summary and recommendations of the Fourth International Workshop‐Conference pm gestational diabetes mellitus. Diabetes Care. 1998;21(Suppl 2):B161-7. [pmid: 9850486].
33 Schwartz M, Ray W, Lubarsky S. The diagnosis and classification of gestational diabetes mellitus: is it time to change our tune?. Am J Obstet Gynecol. 1999;180(6):1560-71. [pmid: 10368504].
34 Sermer M, Naylor C, Gare D, et al. Impact of time since last meal on the gestational glucose challenge test. The Toronto Tri‐Hospital Gestational Diabetes Project. Am J Obstet Gynecol. 1994;171(3):607-16. [pmid: 8092205].
35 Bartha J, Martinez‐Del‐Fresno P, Comino‐Delgado R. Gestational diabetes mellitus diagnosed during early pregnancy. Am J Obstet Gynecol. 2000;182(2):346-50. [pmid: 10694335].
36 Griffin M, Coffey M, Johnson H, et al. Universal vs. risk factor‐based screening for gestational diabetes mellitus: detection rates, gestation at diagnosis and outcome. Diabet Med. 2000;17(1):26-32. [pmid: 10691156].
37 Santini DL, Ales KL. The impact of universal screening for gestational glucose intolerance on outcome of pregnancy. Surg Gynecol Obstet. 1990;170:427-36. [pmid: 2326724].
38 Garner P, Okun N, Keely E, et al. A randomized controlled trial of strict glycemic control and tertiary level obstetric care versus routine obstetric care in the management of gestational diabetes: A pilot study. Am J Obstet Gynecol. 1997;177(1):190-5. [pmid: 9240606].
39 Walkinshaw S. Dietary regulation for 'gestational diabetes' 2000. Cochrane Database of Systemic Reviews 2000;(2):CD000070.
40 Kjos SL, Schaefer‐Graf U, Sardesi S, et al. A randomized controlled trial using glycemic plus fetal ultrasound parameters versus glycemic parameters to determine insulin therapy in gestational diabetes with fasting hyperglycemia. Diabetes Care. 2001;24:1904-10. [pmid: 11679455].
41 Langer O, Anyaegbunam A, Brustman L, Divon M. Management of women with one abnormal oral glucose tolerance test value reduces adverse outcome in pregnancy. Am J Obstet Gynecol. 1989;161:593-9. [pmid: 2675597].
42 Persson B, Strangenberg M, Hansson U, Norlander E. Gestational diabetes mellitus (GDM) comparative evaluation of two treatment regimens, diet versus insulin and diet. Diabetes. 1985;11:101-5. [pmid: 14461447].
43 Kerbel D, Glazier R, Holzapfel S, Yeung M, Lofsky S. Adverse effects of screening for gestational diabetes: a prospective cohort study in Toronto, Canada. J Med Screen. 1997;4(3):128-32. [pmid: 9368868].
44 Sjogren B, Robeus N, Hansson U. Gestational diabetes: a case‐control study of women's experience of pregnancy, health and the child. J Psychosomatic Res. 1994;38(8):815-22.
45 Langer N, Langer O. Emotional adjustment to diagnosis and intensified treatment of gestational diabetes. Obstet Gynecol. 1994;84(3):329-34. [pmid: 8058225].
46 Spirito A, Williams C, Ruggiero L, Bond A, McGarvey S, Coustan D. Psychological impact of the diagnosis of gestational diabetes. Obstet Gynecol. 1989;73(4):562-6. [pmid: 2648224].
47 Feig D, Chen E, Naylor C. Self‐perceived health status of women three to five years after the diagnosis of gestational diabetes: A survey of cases and matched controls. Am J Obstet Gynecol. 1998;178(2):386-93. [pmid: 9500504].
48. Langer O, Levy J, Brustman L, Anyaegbunam A, Merkatz R, Divon M. Glycemic control in gestational diabetes mellitus—how tight is tight enough: small for gestational age vs. large for gestational age?. Am J Obstet Gynecol. 1989;161:646-53. [pmid: 2782347].
49 Knopp RH, Magee MS, Raisys V, Benedetti T, Bonet B. Hypocaloric diets and ketogenesis in the management of obese gestational diabetic women. J Am Coll Nutr. 1991;10:649-67. [pmid: 1770194].
50 Canadian Task Force on the Periodic Health Examination. Screening for gestational diabetes mellitus Can Med Assoc J 1992 147 435 43 1306050 1336242