# Recommendations of Others

The American Diabetes Association recommends screening all women at risk for GDM. The ADA considers women to be at risk for GDM unless they are younger than 25 years, have normal body weight, are not a member of a high‐risk ethnic group, have no first‐degree relatives with diabetes, and have no personal history of glucose intolerance or poor obstetrical outcome.^5^ A 2001 Practice Bulletin of the American College of Obstetricians and Gynecologists (ACOG) recommends a similar risk‐based approach, but notes that since only a small percentage of patients meet criteria for low risk, universal 50‐g 1‐h GCT screening may be a more practical approach.^6^ The Canadian Task Force on Preventive Health Care concluded in 1991 that the available evidence did not support a recommendation for or against universal screening for GDM.^50^