# References and Notes

Current as of February 2002

Internet Citation:

Screening for Breast Cancer. Recommendations and Rationale. February 2002. Agency for Healthcare Research and Quality, Rockville, MD. http://www.ahrq.gov/clinic/3rduspstf/breastcancer/brcanrr.htm

1 U.S. Preventive Services Task Force Guide to Clinical Preventive Services, Second Edition, Washington, DC. Office of Disease Prevention and Health Promotion1996 190016
2 Humphrey LL, Helfand M, Chan BKS. Breast cancer screening with mammography. Summary of the Evidence for the U.S. Preventive Services Task Force (forthcoming).
3 Humphrey LL, Chan BKS, Detlefsen S, Helfand M Screening for Breast Cancer: Systematic Evidence Review, Rockville, MD. Agency for Healthcare Research and Quality (forthcoming)
4 American Cancer Society Cancer facts and figures, 2001-2002, Atlanta, Georgia. American Cancer Societyhttp://www.cancer.orgAccessed February 18, 2002
5 National Cancer Institute Surveillance, Epidemiology, and End Results Program 1995-1997http://www.nci.nih.govAccessed February 18, 2002
6 Mushlin AI, Kouides RW, Shapiro DE Estimating the accuracy of screening mammography: a meta-analysis Am J Prev Med 1998 142143 53 9631167
7 Elmore JG, Barton MB, Moceri VM, et al Ten-year risk of false positive screening mammograms and clinical breast examinations N Engl J Med 1998 338161089 96 9545356
8 Kerlikowske K, Carney PA, Geller B, et al Performance of screening mammography among women with and without a first-degree relative with breast cancer Ann Intern Med 2000 13311855 63 11103055
9 Barton MB, Harris R, Fletcher SW Does this patient have breast cancer?: The screening clinical breast examination: should it be done? How? JAMA 1999 282131270 80 10517431
10 Bobo JK, Lee NC, Thames SF Findings from 752,081 clinical breast examinations reported to a national screening program from 1995 through 1998 J Natl Cancer Inst 2000 9212971 6 10861308
11 Shapiro S. Periodic screening for breast cancer: the HIP Randomized Controlled Trial Health Insurance Plan. J Natl Cancer Inst Monogr. 1997:27-30.
12 Bjurstam N, Bjorneld L, Duffy SW, et al The Gothenburg breast screening trial: first results on mortality, incidence, and mode of detection for women ages 39-49 years at randomization Cancer 1997 80112091 99 9392331
13 Frisell J, Lidbrink E, Hellstrom L, Rutqvist LE. Followup after 11 years-update of mortality results in the Stockholm mammographic screening trial. Breast Cancer Research & Treatment. 1997;45:263-70. [pmid: 9386870].
14 Andersson I, Janzon L. Reduced breast cancer mortality in women under age 50: updated results from the Malmo Mammographic Screening Program. J Natl Cancer Inst Monogr. 1997:63-7.
15 Tabar L, Vitak B, Chen HH, et al The Swedish Two-County Trial twenty years later: Updated mortality results and new insights from long-term follow-up Radiol Clin North Am 2000 384625 51 10943268
16 Alexander FE, Anderson TJ, Brown HK, et al 14 years of follow-up from the Edinburgh randomised trial of breast-cancer screening Lancet 1999 35391681903 08 10371567
17 Miller AB, Baines CJ, To T, Wall C. Canadian National Breast Screening Study: 1. Breast cancer detection and death rates among women aged 40 to 49 years [published erratum appears in Can Med Assoc J 1993 Mar 1;148(5):718]. CMAJ. 1992;147:1459-76. [pmid: 1423087].
18 Miller AB, Baines CJ, To T, Wall C. Canadian National Breast Screening Study: 2. Breast cancer detection and death rates among women aged 50 to 59 years [published erratum appears in Can Med Assoc J 1993 Mar 1;148(5):718]. CMAJ. 1992;147:1477-88. [pmid: 1423088].
19 Miller AB, To T, Baines CJ, Wall C. The Canadian National Breast Screening Study: update on breast cancer mortality. J Natl Cancer Inst Monogr. 1997:37-41.
20 Harris RP, Helfand M, Woolf SH, et al Methods of the third U.S. Preventive Services Task Force Am J Prev Med 2001 203S21 35 11306229
21 Olsen O, Gotzche PC Screening for breast cancer with mammography The Cochrane Library42001
22 Cox BVariation in the effectiveness of breast screening by year of follow-up J Natl Cancer Inst Monogr 19972269 72
23 Nystrom L, Rutqvist LE, Wall S, et al Breast cancer screening with mammography: overview of Swedish randomised trials Lancet 1993 3418851973 78 8096941
24 Thomas DB, Gao DL, Self SG, et al Randomized trial of breast self-examination in Shanghai: methodology and preliminary results J Natl Cancer Inst 1997 895355 65 9060957
25 Semiglazov VF, Moiseenko VM, Manikhas AG, et al Interim results of a prospective randomized study of self-examination for early detection of breast cancer Vopr Onkol 1999 453265 71 10443229
26 UK Breast Cancer Detection Working Group 16-year mortality from breast cancer in the UK trial of early detection of breast cancer Lancet 1999 35391681909 14 10371568
27 Harvey BJ, Miller AB, Baines CJ, Corey PN Effect of breast self-examination techniques on the risk of death from breast cancer CMAJ 1997 15791205 12 9361639
28 Fletcher SW, Harris RP, Gonzalez JJ, et al. Increasing mammography utilization: a controlled study. J Natl Cancer Inst. 1993;85:112-20. [pmid: 8418300].
29 Schwartz LM, Woloshin S, Sox HC, Fischhoff B, Welch HG US women's attitudes to false positive mammography results and detection of ductal carcinoma in situ: cross sectional survey Br Med J 2000 32072501635 40 10856064
30 Feig SA, Hendrick RE Radiation risk from screening mammography of women aged 40-49 years J Natl Cancer Inst Monogr 199722119 24 9709287
31 American Medical Association. Report 16 of the Council on Scientific Affairs (A-99). Mammographic Screening for Asymptomatic Women. June 1999. (http://www.ama-assn.org/ama/pub/article/2036-2346.html). Accessed January 2002.
32 Feig SA, D'Orsi CJ, Hendrick RE, et al American College of Radiology guidelines for breast cancer screening Am J Roentgenol 1998 171129 33 9648758
33 ACS guidelines for the early detection of breast cancer: update 1997 CA Cancer J Clin 1997 473150 53 9152172
34 American College of Obstetricians and Gynecologists Primary and preventive care: periodic assessments ACOG Committee Opinion 246, Washington, DC. ACOG2000 384376
35 Canadian Task Force on the Periodic Health ExaminationOttawa (Canada): Health Canada; 1994. pp. 788-795 (reaffirmed by the Canadian Task Force on the Periodic Health Examination 1999). (http://www.ctfphc.org/index.html). Accessed February 18, 2002
36 Periodic Health Examinations. Summary of AAFP Policy Recommendations & Age Charts (http://www.aafp.org/exam). Accessed January 2002.
37 Ferrini R, Mannino E, Ramsdell E, Hill L Screening Mammography for Breast Cancer: American College of Preventive Medicine Practice Policy Statement Am J Prev Med 1996 125340 41 8909643
38 Royal New Zealand College of General Practitioners, Wellington, New Zealand. Early detection of breast cancer. 1999:p 61.
39 NIH Consensus Statement Online 1997 1511 35 (http://odp.od.nih.gov/consensus/cons/103/103_statement.htm). Accessed December 12, 2001 307522
40 Preventive health care, 2001 update: screening mammography among women aged 40-49 years at average risk of breast cancer. (http://www.ctfphc.org). Accessed January 2002.
41 Preventive health care, 2001 update: Should women be routinely taught breast self-examination to screen for breast cancer? CMAJ 2001 16431837 1846 11450279