# Scientific Evidence

## Epidemiology and Clinical Consequences

Gestational diabetes mellitus is defined as glucose intolerance with onset or first detection during pregnancy.^6^ ^,^ ^7^ GDM occurs in 2‐5 percent of all pregnancies, or approximately 135,000 cases annually in the United States.^6^ Major risk factors for developing GDM include increasing maternal age, family history of diabetes, history of GDM in a prior pregnancy, and increased pregravid BMI.^8^ The prevalence of GDM varies in direct proportion to the prevalence of type‐2 diabetes in a given population or ethnic group.^6^ GDM is more common among African American, Hispanic, and American Indian women and less common among Asian women. Variations in screening practices and in other risk factors make it difficult to quantify the independent contribution of race and ethnicity to developing GDM.

Prevalence of GDM in women with defined low‐risk factors, such as being of white ethnic origin, being younger than 25 years, and having a BMI of less than 25 kg/m2, ranges from 1.4 percent to 2.8 percent.^9^‐^14^ The prevalence of GDM in women with defined high‐risk factors, such as being older than 25 years, being obese, or having a family history of diabetes, ranges from 3.3 percent to 6.1 percent.^11^

GDM has been linked to increased maternal perinatal morbidity (resulting from an increase in cesarean deliveries and forceps or vacuum extraction, as well as third‐ and fourth‐degree lacerations), principally through its association with fetal macrosomia.^15‐22^

Macrosomia is associated with an increased risk for neonatal adverse effects, such as brachial plexus injuries (most of which are temporary) and clavicular fracture.^17^ ^,^ ^21^ ^,^ ^23^‐^24^ Data on the overall impact of GDM screening and treatment on these outcomes is limited because most babies with macrosomia are born to mothers without GDM,^15,^ ^25^‐^29^ and most cases of injuries related to shoulder dystocia occur in pregnancies with infants of normal birthweight. The relationship between GDM and adverse outcomes is further confounded by the fact that maternal obesity is an independent risk factor for many of the same outcomes.^16^ ^,^ ^30^ ^,^ ^31^ The tendency of clinicians to manage differently women who bear the diagnosis of GDM from those who do not may contribute to the observed increase in risk for cesarean delivery in women with GDM.^4^

## Accuracy and Reliability of Screening Tests

Defining the performance characteristics of screening strategies for GDM is complicated by the lack of a universally accepted "gold standard" for diagnosis of GDM. Different diagnostic tests are used in North America and in Europe.^4^ ^,^ ^32^‐^33^ Diagnostic criteria in the United States are based on a 100‐g 3‐h OGTT, but these criteria were originally developed for their ability to identify mothers at risk for developing diabetes, not those whose newborns were at risk for macrosomia or other complications. Expert groups have proposed different criteria for diagnosis based on the 3‐h OGTT; although all the diagnostic criteria predict risk for macrosomia, evidence is weak to support any particular diagnostic standard for GDM. More liberal criteria increase the number of women diagnosed with GDM by more than 50 percent but may not reduce the prevalence of fetal macrosomia.^32^

Screening for GDM in North America is based on a 50‐g 1‐h GCT, usually performed during the 24th to 28th week of gestation. Two thresholds for an abnormal screen have been proposed by different experts:

- A venous plasma glucose cutoff of 130 mg/dL identifies more than 90 percent of all women with a positive 100‐g 3‐h OGTT.
- A higher cutoff of 140 mg/dL detects 80 percent of women with an abnormal OGTT but reduces the number of false positives, 34 which are common for the GCT.

Fewer than 1 in 5 women with a positive GCT will meet criteria for GDM on a full OGTT.^35^ The reliability of the GCT is questionable for one‐third of women with GDM; in one study, screening performed on 2 successive days produced different results.^14^ Data to support specific timing for screening also are sparse. Women who develop GDM early in pregnancy are at higher risk for neonatal hypoglycemia and other GDM‐related outcomes than are those who develop GDM later in pregnancy.^36^ Screening earlier in pregnancy detects fewer women with GDM, but identifies those at highest risk and allows for earlier intervention. Screening for GDM later in pregnancy detects a larger number of women with GDM, many of whom are at lower risk, but who would be treated for a shorter time.

## Effectiveness of Early Detection

No properly conducted randomized controlled trial (RCT) has examined the benefit of universal or selective screening for GDM compared with no screening. The only RCT that attempted to evaluate the effects of universal versus selective screening had important methodologic and analytic flaws. The differences in the timing of screening and the treatments in the study groups make it difficult to draw any conclusions about the benefits of screening.^36^ A retrospective analysis that found similar rates of macrosomia in screened and unscreened populations cannot rule out an effect of screening, because screened women may have been at higher risk for GDM than unscreened women, and the study may not have been large enough to detect a benefit.^37^ One well‐conducted prospective cohort study suggests that screening and diagnosis can reduce macrosomia but that other health outcomes were not affected.^38^

A proposed benefit of screening is that the diagnosis of GDM may lead to interventions to reduce the risk for mothers of developing diabetes later. The USPSTF found no evidence to determine whether diagnosis leads to important lifestyle changes for such women; many of the proposed interventions (e.g., weight loss and exercise) could be recommended for these women on other grounds, independent of their risk for developing diabetes.

Data on the effects of diet therapy alone for treating GDM are limited. An overview of four RCTs found no significant benefits of diet, but the studies were small and had other limitations.^39^ Randomized trials have shown that adding insulin to diet therapy, compared with diet therapy alone, can reduce the incidence of macrosomia, but they have not shown improvement in other important maternal or perinatal outcomes such as cesarean delivery rates, birth trauma, or perinatal mortality.^40^‐^42^ These trials are hampered by small size and lack of power for detecting small changes in more important health outcomes.

Even if screening and treatment are effective, the benefits of widespread screening as a means for preventing birth trauma due to macrosomia are likely to be small. Modeling done for the USPSTF, which assumed that treatment with insulin would reduce the risk of having an infant with macrosomia in mothers with GDM by 75 percent, calculated that nearly 7,000 women at high risk, and 9,000 women at average risk, would need to be screened to prevent 1 case of brachial plexus injury. Although serious, 80 percent of such injuries resolve within the first year.

## Potential Harms of Screening and Treatment

Data are insufficient to make conclusive statements about possible harms of screening for GDM. Screening generates frequent false‐positive results requiring the inconvenience of further testing. One study raises the possibility that the diagnosis of GDM may influence provider decisionmaking and could increase cesarean delivery rates, despite measures taken to decrease the risk for fetal macrosomia.^31^ This study evaluated the rates of cesarean delivery related to birth weight and GDM. In this study, women who were diagnosed and treated for GDM had substantially higher rates of cesarean delivery (34 percent) than controls (20 percent) even though rates of macrosomia were comparable. In a second control group, in which clinicians were not informed that women had borderline GDM, rates of macrosomia were higher than rates among treated women, yet cesarean delivery rates were slightly lower (30 percent) and other birth outcomes (lacerations) were comparable.

The data are limited and mixed as to whether the diagnosis of GDM adversely affects women's perception of their health during pregnancy.^43^‐^46^ Limited data suggest that the diagnosis of GDM may have long‐term effects on women's perception of their health.^45^ ^,^ ^47^ Potential adverse effects of treatment strategies for GDM include increased maternal starvation ketosis resulting from aggressive glycemic‐lowering therapy, and infants who are small for their gestational age. Even uncommon risks are potentially important since nearly 100 women need to be treated with insulin to prevent 1 case of brachial plexus injury due to macrosomia. However, the magnitude of these potential harms has not been evaluated and quantified.^48,^ ^49^

## Cost and Cost‐effectiveness

In the absence of adequate evidence to determine whether selective or universal screening is effective in improving important health outcomes, reliable estimates of cost‐effectiveness of screening are not possible. The cost‐effectiveness of screening depends greatly on the unproven assumption that screening will significantly lower rates of cesarean section and birth trauma. No studies include all relevant cost information related to screening for GDM, including the costs of screening and diagnostic tests, costs of various treatments, and the costs of complications. Reliable estimates of the costs of GDM for women who are not screened are not available.