# Recommendations of Others

The ADA acknowledged that data from prospective studies were insufficient to determine the benefits of diabetes screening and thus concluded that the decision to test for diabetes should be based on clinical judgment and patient preference.^6^ ^6^ On the basis of expert consensus, the ADA recommends clinicians consider screening for diabetes with the FPG test beginning at age 45 years and at a younger age for individuals with such risk factors as family history, overweight, and hypertension, among others. The American College of Obstetricians and Gynecologists endorses the ADA recommendations.^67^ The American Heart Association recommends measuring fasting blood glucose in persons 20 years of age and older according to patient's risk for diabetes, as part of overall risk assessment for cardiovascular disease.^68^ The Canadian Task Force on Preventive Health Care is currently updating its recommendations on diabetes screening.