# Scientific Evidence

## Epidemiology and Clinical Consequences

The burden of suffering caused by type 2 diabetes is enormous. Among individuals aged 40‐74, the prevalence increased from 8.9 percent for the period 1976‐80, to 12.3 percent for the period 1988‐94.^4^ Current prevalence in the United States is likely even higher due to the increasing prevalence of obesity.^5^ Patients with type 2 diabetes are at increased risk for both microvascular and macrovascular disease. Microvascular disease contributes to high rates of blindness, end stage renal disease, and lower extremity amputations. Macrovascular disease accounts for a 2 to 4‐fold increased risk for heart disease and stroke. In addition, a substantial number of people who have elevations in blood glucose not meeting criteria for diabetes (impaired fasting glucose or impaired glucose tolerance) are at increased risk for progression to diabetes and for cardiovascular disease.

The 10‐year incidence of blindness among those with type 2 diabetes of 20‐25 years' duration is between 5 and 15 percent, and the 10‐year incidence of visual deterioration (doubling of the visual angle) is between 35 and 45 percent, with the higher rates for those requiring insulin.^6^ The highest risk is among those who have a longer time to develop visual complications because of onset of diabetes at a younger age.^7^‐^8^

Some patients with diabetes manifest diabetic nephropathy, a condition that can progress to chronic renal failure (CRF). The incidence of CRF among those without macroalbuminuria at diagnosis of type 2 diabetes is about 0.5 percent after 15 years of diabetes duration and 10 percent after 30 years. The incidence of CRF is substantially higher (about 12 percent after 15 years) among those with macroalbuminuria at time of diagnosis of diabetes.^9^

Two cohort studies found that the 20‐25‐year cumulative incidence of lower extremity amputation (LEA) in patients with type 2 diabetes is between 3 and 11 percent.^10^‐^11^ In the United Kingdom Prospective Diabetes Study (UKPDS) cohort, between 1 and 2 percent of participants had had an amputation within 10 years^12^. In the Wisconsin Epidemiologic Study of Diabetic Retinopathy population‐based cohort, about 7 percent of those with type 2 diabetes of short duration had had an amputation within 14 years.^13^

Elevated blood glucose is an independent risk factor for cardiovascular disease (CVD). The risk increases with the level of glucose. The absolute prevalence of established CVD at diagnosis of type 2 diabetes ranges from 8 to 23 percent (depending on the presence of other CVD risk factors) and at least 14 prospective cohort studies have found that the risk for CVD events in diabetic men is about twice that in nondiabetics, even after adjusting for age, hypertension, dyslipidemia, and smoking.^3^ For women, the adjusted CVD risk among diabetics is elevated as much as fourfold compared with nondiabetics. In the UKPDS cohort of diabetic patients undergoing conventional treatment, there were 17 events of myocardial infarction (MI), 5 events of stroke, and 12 events of diabetes‐related deaths, respectively, per 1,000 patient‐years.^12^

Diabetes also imposes a significant economic burden. In 1997, the U.S. health care system spent some $98 billion on medical care and lost productivity for people with type 2 diabetes.^14^ Many individuals who satisfy the criteria for type 2 diabetes have not been diagnosed. Data from the third National Health and Nutrition Examination Survey (NHANES III) showed that 3 percent of the adult population aged 20 and older had not been diagnosed and yet met the diagnostic criteria for diabetes.^4^

## Accuracy and Reliability of Screening Tests

Determining the accuracy of screening tests for type 2 diabetes is complicated by uncertainty of what is the most appropriate gold standard for comparison. Definitions of diabetes were originally developed using results of 2‐hour PG to identify a population at substantially increased risk for retinopathy. The criterion for an abnormal FPG level was developed based on 2‐hour PG, and recently revised downward (from 140 mg/dL to 126 mg/dL) to make the sensitivity of FPG comparable with that of 2‐hour PG. Additional criteria—impaired fasting glucose (110‐125 mg/dL) and impaired glucose tolerance (140‐199 mg/dL for 2‐hour PG)—have been developed to define persons who have less severe elevations of blood glucose. A study using NHANES III data demonstrated that, compared with FPG, the 2‐hour PG as a screening test leads to more individuals being diagnosed as diabetic.^4^

Large population‐based studies have examined the sensitivity of 2‐hour PG, FPG, and HbA1c for identifying patients with retinopathy. Sensitivity and specificity for detecting retinopathy were in the range of 75‐80 percent for all three tests using the following thresholds: FPG [underlined: >]126 mg/dL, 2‐hour PG [underlined: >] 200 mg/dL, or HbA1c [underlined: >]6.4 percent.^15^‐^17^ Other studies have examined whether these tests predict future cardiovascular disease (CVD) events. A recent meta‐regression analysis of 20 observational studies found that both FPG and 2‐hour PG were significantly associated with future CVD events in a continuous graded fashion, beginning at levels consistent with impaired glucose tolerance (IGT) and impaired fasting glucose (IFG) and increasing more steeply at the highest glucose levels.^18^ Among those with previously undiagnosed type 2 diabetes who are in the low range of "diabetic level" FPG (i.e., FPG between 126 and 140 mg/dL), HbA1c was normal in about 60 percent of those tested, indicating it may be less sensitive for detecting lower levels of hyperglycemia.

In clinical practice, the requirement for a screening test to be fasting (as with the FPG) or post‐glucose load (as with 2‐hour PG) presents logistical problems. A well‐conducted, population‐based study found that random CBG had sensitivity and specificity in the 75‐80 percent range for detecting type 2 diabetes defined by older criteria (i.e., FPG [underlined: >] 140 mg/dL or 2‐hour PG greater than or equal to 200 mg/dL), but only if results were interpreted according to age and time since last meal.^19^

## Effectiveness of Early Treatment

No trial has been conducted to establish whether systematic screening for diabetes improves health outcomes compared with usual care. Establishing the health benefits of screening for type 2 diabetes is complex because under current practice many patients with diabetes are detected through haphazard screening: about 50 percent of adults over 45 may have been screened for diabetes in a 3‐year period.^20^

The USPSTF attempted to compare the expected health outcomes from a strategy of systematic screening to those from existing care. In the absence of direct evidence from a trial of screening, the USPSTF examined indirect evidence to estimate whether screening, early diagnosis, and treatment of type 2 diabetes were likely to improve four health outcomes compared with usual care/clinical detection:

- Visual impairment.
- Chronic renal failure.
- Lower extremity amputations.
- CVD events.

Additionally, the results from recent RCTs demonstrate the effectiveness of intensive lifestyle interventions in reducing the incidence of diabetes in individuals with impaired fasting glucose or impaired glucose tolerance. Three large trials in the United States, Finland, and China have demonstrated that intensive programs of lifestyle modification (diet, exercise, and behavior modification) can reduce incidence of diabetes by up to 58 percent in these patients.^21^‐^23^

### Visual Impairment

Although early retinopathy is present in a substantial portion of patients with diabetes at the time of initial diagnosis, severe retinopathy (i.e., that requiring treatment) and visual problems usually develop later in the course of disease. Two well‐performed RCTs have shown that tight glycemic control reduces the relative risk for development or progression of retinopathy by 29‐40 percent.^12^‐^24^ After 10 years of followup in the UKPDS, 7.6 percent of those in the tight control group required laser photocoagulation compared with 10.3 percent of patients in the conventional treatment arm; however, no difference in visual outcomes was detected.^25^ ^,^ ^26^ One large well‐performed RCT found that tighter control of systolic blood pressure (improvement of approximately 10 mm Hg) among hypertensive diabetics decreased the need for retinal photocoagulation by an absolute 4.1 percent and reduced deterioration in visual acuity by an absolute 9.2 percent over 7.5 years.^27^ The incidence of blindness, however, was similar in both groups (3.3 percent vs. 2.4 percent) in this study.

The USPSTF concluded that, although retinal photocoagulation is effective in reducing the incidence of visual impairment among those with severe retinopathy or macular edema, most patients detected by routine screening will not require this intervention. Further, although tight glycemic control reduces the development and progression of retinopathy, its effects on serious visual impairment are less clear and probably occur 10 years or more after the diagnosis of diabetes. The degree to which tight glycemic control during the preclinical period between screening and clinical detection (when glucose levels are lower compared with later stages of the disease) reduces retinopathy and later visual impairment is even less certain.

### Chronic Renal Failure

Three treatments have been examined to reduce the incidence of CRF among diabetics: tight glycemic control, tight blood pressure control, and medications that interrupt the angiotensin‐renin system (angiotensin converting enzyme [ACE] inhibitors and angiotensin receptor blockers [ARBs]).

Evidence from several RCTs shows that tight glycemic control, and tight blood pressure control, reduce the development and progression of albuminuria in those with type 2 diabetes, but neither intervention had a statistically significant effect on the incidence of CRF.^12^ ^,^ ^24^ ^,^ ^27^ Good evidence shows that ACE inhibitors or ARBs, or both, reduce the development and progression of albuminuria and CRF among those with type 2 diabetes.^28^‐^37^ Two of these studies, both involving diabetics with macroalbuminuria, found a reduction in CRF in patients taking ARBs compared with placebo.^32^ ^,^ ^33^ Evidence is mixed as to whether ACE inhibitors are more effective than beta‐blockers in reducing development and progression of albuminuria.

Between 3 and 8 percent of individuals with diabetes (detected clinically or by screening) have macroalbuminuria. As a result, most patients detected by screening will be at low risk (<1 percent) for developing CRF over the next 15 years.

The USPSTF concluded that, although tight glycemic and blood pressure control and use of ACE inhibitors and ARBs reduce the development and progression of albuminuria, it could not determine whether initiating these treatments earlier as a result of screening would have an important impact on CRF.

### Lower Extremity Amputations

Three types of treatment have been tested to reduce LEA: tight glycemic control, tight blood pressure control, and foot care programs. The UKPDS reported a trend toward a lower incidence of amputations with both tight glycemic control^12^ and tight blood pressure control^27^, but the differences did not attain statistical significance. A recent well‐conducted systematic review examined the efficacy of foot care programs on the incidence of foot ulcers and amputations, and its findings were inconclusive.^38^ Well‐conducted trials of diabetics at high risk for foot ulcers found that intensive programs including patient education, special shoes, and health care interventions can reduce the incidence of both foot ulcers and LEAs by as much as 60 percent.^39^ ^,^ ^40^

The USPSTF concluded that LEA in diabetics occurs primarily as a late complication related to the development of distal sensory neuropathy and peripheral vascular disease, both of which take time to develop. Although foot care programs, and perhaps tight glycemic and blood pressure control, may reduce LEA over the long term, the Task Force found no evidence that early implementation of these interventions during the time between screening and clinical detection would have an impact on the later development of LEA.

### Cardiovascular Disease

Four treatments to reduce the incidence of CVD events among patients with diabetes have been studied in high‐quality RCTs: tight glycemic control, tight blood pressure control, treatment of dyslipidemia, and aspirin. No RCT has demonstrated a statistically significant reduction in total CVD events from tight glycemic control. The UKPDS trial (after 10 years of followup) showed a trend toward reduced CVD events in patients randomized to tight glycemic control.^12^ These patients had lower rates of myocardial infarction (14.7 vs. 17.4 events per 1,000 patient‐years) and sudden death (0.9 vs. 1.6 events per 1,000 patient‐years) than those receiving conventional management. Further, there were no reductions in stroke (Relative Risk [RR], 1.11), heart failure (RR, 0.91), angina (RR, 1.02), or all‐cause mortality (RR, 0.94).

A number of recent RCTs have examined various aspects of the treatment of hypertension among patients with type 2 diabetes. Principal findings are that an aggressive approach to blood pressure control among patients with diabetes reduces CVD events by a relative 50 percent^27^ ^,^ ^41^; treatment of isolated systolic hypertension among older patients with diabetes reduces CVD events by a relative 34‐69 percent^42^ ^,^ ^43^; treatment of those with diabetes and at least one other CVD risk factor with ramipril (regardless of whether they have hypertension) reduces CVD events by a relative 22 percent and all‐cause mortality by a relative 16 percent^37^; and ACE inhibitors and ARBs are useful antihypertensive agents for diabetics.^41^ ^,^ ^44^

Several secondary prevention trials of treatments for patients with lipid abnormalities had enough patients with diabetes to permit subgroup analyses. Lipid treatment reduced the incidence of coronary heart disease (CHD) events by about the same relative percentage among those with diabetes as among those without diabetes (relative risk reduction between 19 and 42 percent).^45^‐^47^ No primary prevention trial of lipid therapy has included sufficient numbers of patients with diabetes to perform reliable analyses, although trends in these trials are also in the direction of benefit. The Heart Protection Study (HPS) found that including simvastatin in the treatment regimen of diabetic patients reduces major vascular events (myocardial infarction, stroke, and revascularization) from 25 percent to 20 percent, i.e., prevents one major vascular event in 20 patients, over a 5‐year period.^48^ Aspirin reduces CHD in both diabetics and nondiabetics, with a comparable relative risk reduction (about 30 percent) in both groups.^49^‐^51^

## Potential Harms of Screening and Treatment

Screening for type 2 diabetes could cause harm in several ways. A diagnosis of diabetes could potentially cause "labeling" in asymptomatic individuals (i.e., anxiety or a negative change in self‐perception, or both) and could lead to social consequences (e.g., loss of insurability). However, there is little evidence that patients found to have diabetes at screening experience any adverse effect of labeling.^52^ Early detection could subject individuals to the potential risks of treatment for longer than if the diagnosis was made clinically, with uncertain benefits. Finally, screening could produce false‐positive results, especially since there is not yet complete consensus on criteria for diagnosing diabetes in asymptomatic persons. Further complicating the issue are natural history data that show that between 30 and 50 percent of persons labeled as having impaired glucose tolerance or impaired fasting glucose will revert to normal glycemia without developing type 2 diabetes.^53^‐^59^ False‐positive screening tests could contribute to psychological distress, a problem known to exist for other conditions.

Treatments for diabetes are relatively safe. Tight glycemic control at a time when glycemic levels are relatively low (i.e., the time between screening and clinical diagnosis) can induce hypoglycemia. In the UKPDS, 2.3 percent of people on insulin suffered a major hypoglycemic episode each year, as did 0.4‐0.6 percent of those on oral hypoglycemic agents.^12^ ACE inhibitors^60^ and statins^61^ ^,^ ^62^ have reasonably low levels of serious adverse effects. Finally, although the impact of diabetes treatment on quality of life has been a concern, data from RCTs indicate that better glycemic control among symptomatic patients improves quality of life, although these findings may not apply to patients detected by screening during the preclinical phase.^12^ ^,^ ^63^‐^65^

The USPSTF concluded that, despite the potential for harm in patients whose diabetes is detected by screening, the magnitude of the problem is unknown. The potential harm for patients is an important consideration because, even if early detection is assumed to be beneficial, several thousand people in the general population may need to be screened to prevent a single diabetes‐related complication over a 5‐year period.^3^ When screening is targeted to patients with hypertension or hyperlipidemia, however, the number needed to screen to prevent a cardiovascular event is substantially lower.^3^