# Clinical Considerations

- In the absence of evidence of direct benefits of routine screening for type 2 diabetes, the decision to screen individual patients is a matter of clinical judgment. Patients at increased risk for cardiovascular disease may benefit most from screening for type 2 diabetes, since management of cardiovascular risk factors leads to reductions in major cardiovascular events. Clinicians should assist patients in making that choice. In addition, clinicians should be alert to symptoms suggestive of diabetes (i.e., polydipsia and polyuria) and test anyone with these symptoms.
- Screening for diabetes in patients with hypertension or hyperlipidemia should be part of an integrated approach to reduce cardiovascular risk. Lower targets for blood pressure (i.e., diastolic blood pressure [underlined: <]80 mm Hg) are beneficial for patients with diabetes and high blood pressure. The report of the Adult Treatment Panel III of the National Cholesterol Education Program recommends lower targets for low‐density lipoprotein cholesterol for patients with diabetes. Attention to other risk factors such as physical inactivity, diet, and overweight, is also important, both to decrease risk for heart disease and to improve glucose control.
- Three tests have been used to screen for diabetes: fasting plasma glucose (FPG), 2‐hour post‐load plasma glucose (2‐hour PG), and hemoglobin A1c (HbA1c). The American Diabetes Association (ADA) has recommended the FPG test ([underlined: >]126 mg/dL) for screening because it is easier and faster to perform, more convenient and acceptable to patients, and less expensive than other screening tests. The FPG test is more reproducible than the 2‐hour PG test, has less intraindividual variation, and has similar predictive value for development of microvascular complications of diabetes. Compared with the FPG test, the 2‐hour PG test may lead to more individuals being diagnosed as diabetic. HbA1c is more closely related to FPG than to 2‐hour PG, but at the usual cut‐points it is less sensitive in detecting lower levels of hyperglycemia. The random capillary blood glucose (CBG) test has been shown to have reasonable sensitivity (75 percent at a cut‐point of [underlined: >]120 mg/dL) in detecting persons who have either an FPG level [underlined: >]126 mg/dL or a 2‐hour PG level [underlined: >]200 mg/dL, if results are interpreted according to age and time since last meal; however, the random blood glucose test is less well standardized for screening for diabetes.
- The ADA recommends confirmation of a diagnosis of diabetes with a repeated FPG test on a separate day, especially for patients with borderline FPG results and patients with normal FPG levels for whom suspicion of diabetes is high. The optimal screening interval is not known. The ADA, on the basis of expert opinion, recommends an interval of every three years but shorter intervals in high‐risk persons.
- Regardless of whether the clinician and patient decide to screen for diabetes, patients should be encouraged to exercise, eat a healthy diet, and maintain a healthy weight, choices that may prevent or forestall the development of type 2 diabetes. More aggressive interventions to establish and maintain these behaviors should be considered for patients at increased risk for developing diabetes, such as those who are overweight, have a family history of diabetes, or have a racial or ethnic background associated with an increased risk (e.g., American Indians). Intensive programs of lifestyle modification (diet, exercise, and behavior) should also be considered for patients who have impaired fasting glucose or impaired glucose tolerance, since several large trials have demonstrated that these programs can significantly reduce the incidence of diabetes in these patients. Evidence and recommendations regarding counseling about diet, physical activity, and obesity are provided in the USPSTF evidence summaries "Counseling to Promote a Healthy Diet (http://www.ahrq.gov/clinic/uspstf/uspsdiet.htm)," "Counseling to Promote Physical Activity (http://www.ahrq.gov/clinic/uspstf/uspsphys.htm)," and "Screening and Treatment for Obesity in Adults (http://www.ahrq.gov/clinic/uspstf/uspsobes.htm)," available on the Agency for Healthcare Research and Quality Web site at www.preventiveservices.ahrq.gov.