# References

1 U.S. Preventive Services Task Force. Guide to Clinical Preventive Services, 2nd ed. Washington, DC: Office of Disease Prevention and Health Promotion; 1996.
2 Boustani M, Peterson B, Hanson L, Harris R, Lohr K. Screening for Dementia in Primary Care: A Summary of the Evidence for the U.S. Preventive Services Task Force. Ann Int Med. 2003;138:927-37. [pmid: 12779304].
3 Boustani M, Peterson B, Harris R, et al. Screening for Dementia. Systematic Evidence Review No. 20. (Prepared by Research Triangle Institute‐University of North Carolina Evidence‐based Practice Center under Contract No. 290‐97‐0001.) Rockville, MD. Agency for Healthcare Research and Quality. June 2003 (Available on the AHRQ Web site at: http://www.ahrq.gov/clinic/serfiles.htm).
4 American Psychiatric Association, ed. Diagnostic and Statistical Manual of Mental Disorders, 4th ed. Washington D.C.; 1994.
5 Morris J, Storandt M, Miller J, et al. Mild cognitive impairment represents early‐stage Alzheimer disease. Arch Neurol. 2001;58(3):397-405. [pmid: 11255443].
6 Ernst RL, Hay JW. The US economic and social costs of Alzheimer's disease revisited. Am J Public Health. 1994;84(8):1261-4. [pmid: 8059882]. [pmcid: 1615456].
7 Lautenschlager N, Cupples L, Rao V, et al. Risk of dementia among relatives of Alzheimer's disease patients in the MIRAGE study: What is in store for the oldest old?. Neurology. 1996;46(3):641-50. [pmid: 8618660].
8 Blacker D, Tanzi R. The genetics of Alzheimer disease: current status and future prospects. Arch Neurol. 1998;55(3):294-6. [pmid: 9520001].
9 Lai F, Williams R. A prospective study of Alzheimer disease in Down syndrome. Arch Neurol. 1989;46(8):849-53. [pmid: 2527024].
10 Longstreth WJ, Bernick C, Manolio T, Bryan N, Jungreis C, Price T. Lacunar infarcts defined by magnetic resonance imaging of 3660 elderly people: the Cardiovascular Health Study. Arch Neurol. 1998;55(9):1217-25. [pmid: 9740116].
11 Hofman A, Ott A, Breteler M, et al. Atherosclerosis, apolipoprotein E, and prevalence of dementia and Alzheimer's disease in the Rotterdam Study. Lancet. 1997;349(9046):151-4. [pmid: 9111537].
12 Costa PT Jr, Williams T, Somerfield M, et al. Early identification of Alzheimer's disease and related dementias. Clinical Practice Guideline, Quick Reference Guide for Clinicians, No. 19. AHCPR Publication No. 97‐0703. Rockville, MD; 1996:1‐28.
13 Wilder D, Cross P, Chen J, et al. Operating characteristics of brief screens for dementia in a multicultural population. Am J Geriatric Psychiatry. 1995;3(2):96-107.
14 Jitapunkul S, Lailert C, Worakul P, et al. Chula Mental Test: A screening test for elderly people in less developed countries. Int J Geriatr Psychiatry. 1996;11(8):714-20.
15 McDowell I, Kristjansson B, Hill GB, Hebert R. Community screening for dementia: the Mini Mental State Exam (MMSE) and Modified Mini‐Mental State Exam (3MS) compared. J Clin Epidemiol. 1997;50(4):377-83. [pmid: 9179095].
16 Lindeboom J, Launer LJ, Schmand BA, Hooyer C, Jonker C. Effects of adjustment on the case‐finding potential of cognitive tests. J Clin Epidemiol. 1996;49(6):691-5. [pmid: 8656232].
17 Law S, Wolfson C. Validation of a French version of an informant‐based questionnaire as a screening test for Alzheimer's disease. Br J Psychiatry. 1995;167(4):541-4. [pmid: 8829727].
18 Braekhus A, Laake K, Engedal K. A low, 'normal' score on the Mini‐Mental State Examination predicts development of dementia after three years. J Am Geriatr Soc. 1995;43(6):656-61. [pmid: 7775725].
19 Heun R, Papassotiropoulos A, Jennssen F. The validity of psychometric instruments for detection of dementia in the elderly general population. Int J Geriatr Psychiatry. 1998;13(6):368-80. [pmid: 9658272].
20 Birks J, Iakovidou V, Tsolaki M. Rivastigmine for Alzheimer's disease (Cochrane Review). Cochrane Database Syst Rev 2000(2):CD001191.
21 Birks J, Melzer D, Beppu H. Donepezil for mild and moderate Alzheimer's disease (Cochrane Review). Cochrane Database Syst Rev 2000(4):CD001190.
22 Qizilbash N, Whitehead A, Higgins J, Wilcock G, Schneider L, Farlow M. Cholinesterase inhibition for Alzheimer disease: a meta‐analysis of the tacrine trials. Dementia Trialists' Collaboration. JAMA. 1998;280(20):1777-82. [pmid: 9842955].
23 Olin J SL. Galantamine for Alzheimer's disease. Cochrane Database Syst Rev. 2002;3:CD001747.
24 Greenberg S, Tennis M, Brown L, et al. Donepezil therapy in clinical practice: a randomized crossover study. Arch Neurol. 2000;57(1):94-99. [pmid: 10634454].
25 Burns A, Rossor M, Hecker J, et al. The effects of donepezil in Alzheimer's disease—results from a multinational trial. Dement Geriatr Cogn Disord. 1999;10(3):237-44. [pmid: 10325453].
26 Rosler M, Anand R, Cicin‐Sain A, et al. Efficacy and safety of rivastigmine in patients with Alzheimer's disease: international randomised controlled trial. BMJ. 1999;318(7184):633-8. [pmcid: 27767]. [pmid: 10066203].
27 Mohs RC, Doody RS, Morris JC, et al. A 1‐year, placebo‐controlled preservation of function survival study of donepezil in AD patients. Neurology. 2001;57(3):481-8. [pmid: 11502917].
28 Winblad B, Engedal K, Soininen H, et al. A 1‐year, randomized, placebo‐controlled study of donepezil in patients with mild to moderate AD. Neurology. 2001;57(3):489-95. [pmid: 11502918].
29 Petracca G, Teson A, Chemerinski E, Leiguarda R, Starkstein S. A double‐blind placebo‐controlled study of clomipramine in depressed patients with Alzheimer's disease. J Neuropsychiatry Clin Neurosci. 1996;8(3):270-5. [pmid: 8854297].
30 Auchus A, Bissey‐Black C. Pilot study of haloperidol, fluoxetine, and placebo for agitation in Alzheimer's disease. J Neuropsychiatry Clin Neurosci. 1997;9(4):591-3. [pmid: 9447502].
31 Devanand D, Marder K, Michaels K, et al. A randomized, placebo‐controlled dose‐comparison trial of haloperidol for psychosis and disruptive behaviors in Alzheimer's disease. Am J Psychiatry. 1998;155(11):1512-20. [pmid: 9812111].
32 Lyketsos CG, Sheppard JM, Steele CD, et al. Randomized, placebo‐controlled, double‐blind clinical trial of sertraline in the treatment of depression complicating Alzheimer's disease: initial results from the Depression in Alzheimer's Disease study. Am J Psychiatry. 2000;157(10):1686-9. [pmid: 11007727].
33 Teri L, Logsdon RG, Peskind E, et al. Treatment of agitation in AD: a randomized, placebo‐controlled clinical trial. Neurology. 2000;55(9):1271-8. [pmid: 11087767].
34 Oken B, Storzbach D, Kaye J. The efficacy of Ginkgo biloba on cognitive function in Alzheimer disease. Arch Neurol. 1998;55(11):1409-15. [pmid: 9823823].
35 Birks J, Flicker L. Selegiline for Alzheimer's disease (Cochrane Review). Cochrane Database Syst Rev 2000(2):CD000442.
36 Sano M, Ernesto C, Thomas RG, et al. A controlled trial of selegiline, alpha‐tocopherol, or both as treatment for Alzheimer's disease. The Alzheimer's Disease Cooperative Study. N Engl J Med. 1997;336(17):1216-22. [pmid: 9110909].
37 Mulnard RA, Cotman CW, Kawas C, et al. Estrogen replacement therapy for treatment of mild to moderate Alzheimer disease: a randomized controlled trial. Alzheimer's Disease Cooperative Study. JAMA. 2000;283(8):1007-15. [pmid: 10697060].
38 Pantoni L, Rossi R, Inzitari D, et al. Efficacy and safety of nimodipine in subcortical vascular dementia: a subgroup analysis of the Scandinavian Multi‐Infarct Dementia Trial. J Neurol Sci. 2000;175(2):124-34. [pmid: 10831773].
39 Williams P, Rands G, Orrel M, Spector A. Aspirin for vascular dementia. Cochrane Database Syst Rev 2000(4):CD001296.
40 Thompson C, Briggs M. Support for carers of people with Alzheimer's type dementia (Cochrane Review). Cochrane Database Syst Rev 2000(3):CD000454.
41 Tappen RM. The effect of skill training on functional abilities of nursing home residents with dementia. Res Nurs Health. 1994;17(3):159-65. [pmid: 8184127]. [pmcid: 1952655].
42 McCurry SM, Logsdon RG, Vitiello MV, Teri L. Successful behavioral treatment for reported sleep problems in elderly caregivers of dementia patients: a controlled study. J Gerontol B Psychol Sci Soc Sci. 1998;53(2):P122-9. [pmid: 9520929].
43 Marriott A, Donaldson C, Tarrier N, Burns A. Effectiveness of cognitive‐behavioural family intervention in reducing the burden of care in carers of patients with Alzheimer's disease. Br J Psychiatry. 2000;176:557-62. [pmid: 10974962].
44 Mittelman MS, Ferris SH, Steinberg G, et al. An intervention that delays institutionalization of Alzheimer's disease patients: treatment of spouse‐caregivers. Gerontologist. 1993;33(6):730-40. [pmid: 8314099].
45 Brodaty H, Gresham M, Luscombe G. The Prince Henry Hospital dementia caregivers' training programme. Int J Geriatr Psychiatry. 1997;12(2):183-92. [pmid: 9097211].
46 Jorm A, Henderson A, Scott R, Mackinnon A, Korten A, Christensen H. Do mental health surveys disturb? Further evidence. Psychol Med. 1994;24(1):233-7. [pmid: 8208888].
47 Conwell Y, Caine E. Rational suicide and the right to die. Reality and myth. N Engl J Med. 1991;325(15):1100-3. [pmid: 1891013].
48 Rohde K, Peskind E, Raskind M. Suicide in two patients with Alzheimer's disease. J Am Geriatr Soc. 1995;43(2):187-9. [pmid: 7836647].
49 Anonymous. Practice parameter: early detection of dementia: mild cognitive impairment (an evidence‐based review). Report of the quality standards subcommittee of the American Academy of Neurology). Neurology. 2001;56:1133-42. [pmid: 11342677].
50 Canadian Task Force on the Periodic Health Examination. Canadian guide to clinical prevention health care. Ottawa: Canada Communication Group; 1994:902‐9.
51 American Medical Association. Practical guide for the Primary Care Physician on the Diagnosis, Management and Treatment of Dementia. Program on Aging and Community Health. Chicago, IL, 2001. Available at: http://www.ama‐assn.org/ama/pub/category/4789.html (http://www.ama-assn.org/ama/pub/category/4789.html). Accessed Jan 10, 2003.
52 Santacruz KS, Swagerty D. Early diagnosis of dementia. American Family Physician 2001. Available at: http://www.aafp.org/afp/monograph/Accessed Jan 10, 2003.