# References

1 U.S. Preventive Services Task Force. Guide to Clinical Preventive Services, second edition. Washington, DC: Office of Disease Prevention and Health Promotion; 1996.
2 Thompson DC, McPhillips H, Davis RL, Lieu TA, Homer CJ, and Helfand M. Universal newborn hearing screening: summary of evidence. JAMA. 2001;286. [pmid: 11667937].
3 Helfand M, Thompson DC, Davis R, McPhillips H, Homer CJ, Lieu TA. Newborn Hearing Screening: Systematic Evidence Review. Pub. No. AHRQ02-S001. Rockville, MD: Agency for Healthcare Research and Quality; 2001 (forthcoming).
4 Harrison M, Roush J Age of suspicion, identification, and intervention for infants and young children with hearing loss: a national study Ear Hear 1996 17155 62 8741968 331535
5 Joint Committee on Infant Hearing Joint Committee on Infant Hearing Year 2000 Position Statement: Principles and Guidelines for Early Hearing Detection and Intervention Programs Pediatrics 2000 1064798 817http://www.infanthearing.org/jcih/11015525
6 Fortnum H, Davis A Epidemiology of permanent childhood hearing impairment in Trent Region, 1985-1993 Br J Audiol 1997 316409 46 9478287
7 Norton SJ, Gorga MP, Widen JE, et al. Identification of neonatal hearing impairment: evaluation of transient evoked otoacoustic emission, distortion product otoacoustic emission, and auditory brain stem response test performance. Ear Hear. 2000;21:508-28. [pmid: 11059707].
8 Wessex Universal Neonatal Hearing Screening Trial Group. Controlled trial of universal neonatal screening for early identification of permanent childhood hearing impairment. Lancet. 1998;352:1957-64. [pmid: 9872244].
9 Vohr BR, Carty LM, Moore PE, Letourneau K The Rhode Island Hearing Assessment Program: experience with statewide hearing screening (1993-1996) J Pediatr 1998 1333353 7 9738715
10 Johnson JL, Kuntz NL, Sia CC, White KR, Johnson RL Newborn hearing screening in Hawaii Hawaii Med J 1997 5612352 5 9447797 183343
11 Prieve B, Dalzell L, Berg A, Bradley M, Cacace A The New York State universal newborn hearing screening demonstration project: outpatient outcome measures Ear Hear 2000 212139105
12 Kennedy CR Controlled trial of universal neonatal screening for early identification of permanent childhood hearing impairment: coverage, positive predictive value, effect on mothers and incremental yield Acta Paediatr Suppl 1999 8843273 5 10626585
13 Barringer DG, Mauk GW. Survey of parents perceptions regarding hospital-based newborn hearing screening. Audiol Today. 1997;9:18-19. [pmcid: 155930].
14 American Academy of Pediatrics Task Force on Newborn and Infant Hearing. Newborn and infant hearing loss: detection and intervention, 1998-1999 Pediatrics 1999 1032527 30 9925859 248117
15 Pediatricians make new recommendations on hearing screening [press release] American Academy of Pediatrics; April 5, 1999http://www.aap.org
16 Centers for Disease Control, National Center for Birth Defects and Developmental Disabilities, Early Hearing Detection and Intervention Program What is EHDI?http://www.cdc.gov/ncbddd/ehdi/ehdi.htm
17 National Institutes of Health Early identification of hearing impairment in infants and young children 1 24http://text.nlm.nih.gov/nih/cdc/www/92txt.html329510
18 National Center for Hearing Assessment and Management Early identification of hearing loss: implementing universal newborn hearing screening programshttp://www.infanthearing.org/impguide/impguide.pdf
19 American Academy of Pediatrics and American College of Obstetricians and Gynecologists. Guidelines for Perinatal Care, 4th ed. 1997:160-2. [pmcid: 325437].
20 Department of Health Piloting the introduction of universal neonatal screening in Englandhttp://www.doh.gov.uk/uhnspilots/index.htm