# Recommendations of Others

The Joint Committee on Infant Hearing 2000 Position Statement, developed and approved by the American Academy of Audiology, the American Academy of Pediatrics (AAP), the American Speech-Language-Hearing Association (ASHA), the Council on Education of the Deaf, and Directors of Speech and Hearing Programs in State Health and Welfare Agencies, endorses early detection of and intervention for infants with hearing loss (early hearing detection and intervention, [EHDI]) through integrated, interdisciplinary State and national systems of UNHS, evaluation, and family-centered intervention.^5^ Audiologic evaluation and medical evaluations should be in progress before 3 months of age. Infants with confirmed hearing loss should receive intervention before 6 months of age from health care and education professionals with expertise in hearing loss and deafness in infants and young children.^5,14,15^

The Centers for Disease Control and Prevention supports universal newborn hearing screening through its Early Hearing Detection and Intervention (EHDI) Program, which assists states in implementing screening and intervention programs and supports research and data collection on EHDI programs.^16^ A 1993 National Institutes of Health Consensus Development Panel also recommended universal screening for hearing impairment prior to 3 months of age in order to identify and initiate treatment for all hearing-impaired infants by 6 months of age.^17^ A publication promoting the early identification of hearing loss has been published by the Maternal and Child Health Bureau of the Health Resources and Services Administration (HRSA). HRSA supports universal screening and has provided funding to assist States in developing such programs.^18^

The American Academy of Family Physicians (AAFP) and the Canadian Task Force on Preventive Health Care are currently reviewing their positions on universal newborn hearing screening.

The American College of Obstetricians and Gynecologists recommends screening for hearing loss in neonates with any of the following risk factors^19^:

- Family history of hereditary childhood SNHL.
- In utero infection.
- Craniofacial anomalies.
- Birth weight less than 1,500 grams.
- Hyperbilirubinemia requiring exchange transfusion.
- Ototoxic medications.
- Bacterial meningitis.
- Apgar score of 0-4 at 1 minute or 0-6 at 5 minutes after birth.
- Mechanical ventilation lasting 5 days or longer.
- Stigmata or other findings associated with a syndrome known to include a sensorineural or conductive hearing loss.

The British National Coordinating Centre for Health Technology Assessment supports universal neonatal hearing screening, supplemented by a targeted infant distraction test at about 7 months of age, primarily for those children not screened neonatally.^20^