# Scientific Evidence

## Epidemiology and Clinical Consequences

Each year, an estimated 5,000 infants are born in the United States with moderate, severe, or profound bilateral SNHL. The estimated prevalence of bilateral SNHL is 1-2 per 1,000 newborns in the U.S., but may be 10-20 times higher among infants in the NICU than in the healthy nursery population. Prevalence of bilateral SNHL is also increased in infants with other selected risk factors (see Clinical Considerations).

The diagnosis of congenital hearing loss is often delayed. In one survey conducted before hearing screening was common, the median age at diagnosis was 13 months for infants with severe to profound bilateral SNHL and 17 months for those with mild-to-moderate hearing losses.^4^

Children with hearing loss experience delayed development in language, learning, and speech. Impairment exists as early as age 3 years and has consequences throughout life, leading to lower reading abilities, poorer school performance, and under- or unemployment.

## Accuracy, Reliability, and Short-Term Impact of Screening Tests

Between 50 percent and 75 percent of infants with moderate-to-profound bilateral SNHL have one or more specific risk factors (see Clinical Considerations).^5,6^ Until recently, most newborn hearing screening programs in the United States focused on identifying and screening infants at risk for SNHL. However, these programs typically do not identify infants at risk for hearing loss due to failure to administer screening questionnaires or loss to followup, and they will miss affected infants who have no risk factors.

In the late 1990s, the development of rapid, low-cost screening tests made it feasible to implement screening programs for all newborns for congenital hearing loss during the birth hospitalization. Two types of tests are commonly used: otoacoustic emissions (OAEs) and auditory brainstem response (ABR). Typically, screening programs use a two-stage screening approach (either OAE repeated twice, OAE followed by ABR, or automated ABR repeated twice). Criteria for defining a "pass" or "fail" on the initial screening test vary, and results are sensitive to equipment, the tester's training, and ongoing quality control.

The true sensitivity and specificity of newborn hearing screening are difficult to estimate from most screening programs. One large, good-quality study measured the sensitivity and specificity of OAE and ABR using an independent "gold standard," visual reinforcement audiometry, performed at 8 to 12 months.^7^ One-stage screening with an ABR or OAE test can detect 80 to 95 percent of affected ears, depending on how an abnormal test result is defined. The two-stage protocol of OAE and ABR missed 11 percent of affected ears, but was more specific than testing with the ABR or OAE alone. Because the prevalence of SNHL is low, there are many more false positives than true positives, especially in low-risk populations. Overall, 6.7 percent of infants who failed in-hospital screening tests were eventually diagnosed with bilateral SNHL in the best study of newborn hearing screening; among those without risk factors for hearing loss, only 2 percent of those failing such screening tests were later found to have SNHL.^8^

Children who fail in-hospital screening tests are usually referred for repeat testing between 2 and 8 weeks after discharge; positive second-stage results are usually validated by a combination of otolaryngologic and audiologic consultation, diagnostic ABR testing, or other electrophysiologic testing that can be performed as early as age 3 months. Visual reinforcement audiometry cannot be performed reliably before age 8 to 9 months.

Universal newborn hearing screening reduces the age at which infants with hearing loss are diagnosed and treated. Studies of statewide universal newborn hearing screening programs in the United States have found that the mean age of identification of hearing impairment has decreased from 12 to 13 months before screening programs were introduced to 3 to 6 months since their introduction.^9,10^ The mean age at which infants receive hearing aids has been reduced from 13 to 16 months before universal newborn hearing screening programs began to 5 to 7 months^9,11^ following their introduction. In a large controlled study comparing in-hospital UNHS with no screening, UNHS significantly increased the number of infants with hearing loss referred to audiologists by the age of 6 months and increased the probability that infants with moderate and severe hearing loss would be diagnosed by the age of 10 months (57 percent vs 14 percent).^8^ Compared with selective screening of high-risk newborns, universal screening would result in the early diagnosis (before 10 months) of one additional case for every 1,441 infants screened, and early treatment (before 10 months) of one additional case for every 2,401 newborns screened, by one estimate.^2,3^

## Effectiveness of Early Intervention to Improve Language Outcomes

There are no prospective, controlled studies that directly examine whether newborn hearing screening and earlier intervention result in improved speech, language, or educational development.

Although several retrospective studies have variously concluded that infants entering treatment programs at younger ages, or infants identified in hospitals with universal screening programs, have better long-term language outcomes,^2,3^ all of these studies have significant methodological flaws.

All of the available retrospective studies began with a convenience sample of children enrolled in early intervention programs, rather than with an inception cohort of children at the point of identification of hearing loss. None described loss to followup between enrollment in the intervention program and the age of assessment, and criteria for inclusion and exclusion were not clearly described. In most studies, early identification was not necessarily the result of screening. Therefore, underlying differences between children identified or enrolled early and those identified or enrolled late may have contributed to the observed language differences. Although some studies attempted to adjust for appropriate confounding factors, the USPSTF judged that statistical adjustment cannot compensate for the potential biases arising from unbalanced cohort selection, concluding that the studies do not establish the effectiveness of early identification and treatment.

## Other Potential Benefits or Harms of Screening and Treatment

Because UNHS reduces the average age for intervention by 6 to 9 months, improved hearing or increased prelanguage stimulation over that period might, in themselves, be considered important benefits of newborn hearing screening. In addition, there might be a psychological benefit to parents or to hearing-impaired children of avoiding regret in the future due to the delayed diagnosis and treatment of hearing impairment. However, the USPSTF was unable to identify any evidence that would allow it to assess the magnitude of these potential benefits or determine whether they alone were sufficient to offset the potential harms of screening.

Because most positive screening tests are false positives, the most likely potential adverse effects of screening are parental anxiety and misunderstanding, and labeling of normal infants as hearing-impaired until the definitive diagnosis can be made months later. Even a small increased risk of these effects could have a large impact on the net benefit of a screening program. In low-risk populations, there are 25 to 50 false positives for each true case of hearing impairment.^8^ In existing newborn hearing screening programs, 13 percent to 31 percent do not follow up for definitive testing, which might allay concerns about the baby's health.

Findings from studies that evaluated parental anxiety are mixed. In the largest controlled trial of screening, parents whose infants were screened had similar anxiety and attitudes as parents whose infants were not screened.^12^ In another survey, 98 percent of parents said they would give permission for screening, 95 percent said they would prefer screening even if the baby failed, and 85 percent said that anxiety caused by failing a screening test would be outweighed by the potential benefit of early detection.^13^ In other studies, false-positive results produced significant or lasting anxiety in 3 percent to 14 percent of parents, even after followup testing. No studies have evaluated whether parental anxiety has any long-term effect on parent-child interaction.

Because definitive diagnoses may take months to confirm, false-positive diagnosis of SNHL may occasionally lead to unnecessary intervention in an infant who hears normally. In one large screening trial, the initial audiologic diagnosis was incorrect in 2 of 27 infants diagnosed with SNHL (7 percent), and the infants proved to have normal hearing when re-examined at age 4 months or 10 months.^2,3^

The yield of newborn hearing screening is comparable to or higher than that of other well-accepted newborn screening programs. To identify one infant with moderate-to-severe hearing loss, newborn hearing screening would require screening an estimated 600 infants. Relative to selective screening, universal newborn hearing screening requires screening an estimated 1,400 infants to identify one additional affected infant, yields that are comparable to or better than those for newborn screening programs for other disorders, including hemoglobinopathy and phenylketonuria.^1^ Thus, if the effects of screening and subsequent treatment on longer-term language outcomes could be confirmed, the cost-effectiveness of newborn hearing screening might be equal or superior to that of many other newborn screening services.