# References

1 Pignone M, Gaynes BN, Rushton JL, et al Screening for Depression. Systematic Evidence Review No. 6 (Prepared by the Research Triangle Institute-University of North Carolina Evidence-based Practice Center under Contract No. 290-97-0011) AHRQ Publication No. 02-S002, Rockville,, MD:. Agency for Healthcare Research and Quality May 2002
2 Williams JW, Hitchcock Noel P, Cordes JA, Ramirez G, Pignone M. Rational clinical examination. Is this patient clinically depressed?. JAMA. 2002;287:1160-7. [pmid: 11879114].
3 Whooley MA, Avins AL, Miranda J, Browner WS. Case-finding instruments for depression: Two questions are as good as many. J Gen Intern Med. 1997;12:439-45. [pmid: 9229283]. [pmcid: 273603].
4 American Psychiatric Association Diagnostic and Statistical Manual of Mental DisordersDSM-IV4th ed, Washington, DCAmerican Psychiatric Association1994
5 Murray CJ, Lopez AD Global Burden of Disease, Cambridge,, MA. Harvard University Press 1996 190016
6 Depression Guideline Panel Depression in Primary Care: Volume 1. Detection and DiagnosisClinical Practice Guideline, Number 5., Rockville,, MD:. U.S. Department of Health and Human Services1993 AHCPR Publication No. 93-0550 443355
7 Simon GE, VonKorff M. Recognition, management, and outcomes of depression in primary care. Arch Fam Med. 1995;4:99-105. [pmid: 7842160]. [pmcid: 160110].
8 Mulrow CD, Williams JW Jr, Chiquette E, et al. Efficacy of newer pharmacotherapies for treating depression in primary care patients. Am J Med. 2000;108:54-64. [pmid: 11059441].
9 Pignone MP, Gaynes BN, Rushton JL, et al. Screening for depression in adults: a summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2002. [pmid: 12020146]. [pmcid: 321147].
10 Canadian Task Force on the Periodic Health Examination The Canadian Guide to Clinical Health Care, Ottawa, OntarioHealth Canada 1994 450 4
11 American College of Obstetricians and Gynecologists Guidelines for Women's Health Care, Washington, DCAmerican College of Obstetricians and Gynecologists2002 126 33, 235-6,79 116740
12 Suicide and suicide attempts in adolescents Committee on AdolescentsAmerican Academy of PediatricsPediatrics 2000 105 871 4 10742340
13 American Medical Association Guidelines for Adolescent Preventive Services (GAPS): Recommendations Monograph, Chicago:American Medical Association1997 176006