# Recommendations of Others

Nearly all North American organizations support mammography screening, although groups vary in the recommended age to begin screening, the interval for screening, and the role of CBE:

- The American Medical Association (AMA)^31^, the American College of Radiology (ACR)^32^, and the American Cancer Society (ACS),^33^ all support screening with mammography and CBE beginning at age 40.
- The American College of Obstetricians and Gynecologists (ACOG)^34^ supports screening with mammography beginning at age 40 and CBE beginning at age 19.
- The Canadian Task Force on Preventive Health Care (CTFPHC),^35^ the American Academy of Family Physicians (AAFP),^36^ and the American College of Preventive Medicine (ACPM)^37^ recommend beginning mammography for average-risk women at age 50.
- AAFP and ACPM recommend that mammography in high-risk women begin at age 40, and AAFP recommends that all women aged 40-49 be counseled about the risks and benefits of mammography before making decisions about screening.^36,37^

A 1997 Consensus Development Panel convened by the National Institutes of Health concluded that the evidence was insufficient to determine the benefits of mammography among women aged 40-49. This panel recommended that women aged 40-49 should be counseled about potential benefits and harms before making decisions about mammography.^39^ In 2001, the CTFPHC concluded there was insufficient evidence to recommend for or against mammography in women 40-49.^40^

Organizations differ on their recommendations for the appropriate interval for mammography. Annual mammography is recommended by AMA, ACR, and ACS.^31,33,34^ Mammography every 1-2 years is recommended by AAFP, ACPM, and the CTFPHC.^36,36,35^ ACOG recommends mammography every 1-2 years for women aged 40-49 and annually for women aged 50 and older.^32^

In their 2001 report, the Canadian Task Force on Preventive Health Care recommends against teaching breast self-examination to women aged 40-69.^41^ The AMA, ACOG, ACS, and AAFP support teaching BSE.^31,32,34,36^