# Recommendations of Others

The Canadian Task Force on Preventive Health Care (CTFPHC) found fair evidence to exclude routine screening of asymptomatic individuals for depression in 1994 but suggested that clinicians maintain a high degree of clinical suspicion for depression among their patients (10). The CTFPHC is currently revisiting this recommendation. The American College of Obstetricians and Gynecologists recommends that clinicians should be alert to symptoms of depression and question patients about psychosocial stressors and family history of depression when taking their history (11). The American Academy of Pediatrics recommends that pediatricians ask questions about depression in routine history-taking throughout adolescence (12). The American Medical Association recommends screening for depression among adolescents who may be at risk owing to family problems, drug or alcohol use, or other indicators of risk (13).