# References and Notes

1 U.S. Preventive Services Task Force. Guide to clinical preventive services. 2nd ed. Washington, DC: Office of Disease Prevention and Health Promotion, U.S. Government Printing Office, 1996.
2 Pignone MP, Phillips CJ, Atkins D, Teutsch SM, Mulrow CD, Lohr KN. Screening and treating adults for lipid disorders. Am J Prev Med. 2001;20:77-89. [pmid: 11306236]. [pmcid: 140185].
3 Pignone MP, Phillips CJ, Lannon CM, et al. Screening Adults for Lipid Disorders. Systematic Evidence Review. Pub. No. AHRQ01-S004. Rockville, MD: Agency for Healthcare Research and Quality, 2001.
4 Wilson PW, D'Agostino RB, Levy D, Belanger AM, Silbershatz H, Kannel WB. Prediction of coronary heart disease using risk factor categories. Circulation. 1998;97:1837-1847. [pmid: 9603539].
5 Jackson R Updated New Zealand cardiovascular disease risk-benefit prediction guide BMJ 2000 320 709 10www.bmj.com/cgi/content/full/320/7236/70910710588
6 Summary of the second report of the National Cholesterol Education Program (NCEP) Expert Panel on the Detection, Evaluation, and Treatment of High Blood Cholesterol in Adults (Adult Treatment Panel II). JAMA. 1993;269:3015-23. [pmid: 8501844].
7 Grundy SM, Balady GJ, Criqui MH, et al. A statement for healthcare professionals from the Task Force on Risk Reduction, Consensus Panel Statement (AHA). Circulation. 1997;95. [pmcid: 34195].
8 American College of Obstetricians and Gynecologists (ACOG), Committee on Primary Care. Primary and Preventive Care: Periodic Assessments. Committee Opinion No. 229. Washington, DC: ACOG; December 1999.
9 American Academy of Family Physicians. Clinical recommendations: 2000-2001. Leawood, KS: American Academy of Family Physicians; 2001. In press. Also available at www.aafp.org/exam/.
10 Garber AM, Browner WS, Hulley SB. Clinical guideline, Part II: cholesterol screening in asymptomatic adults, revisited. Ann Intern Med. 1996;124:518-531. [pmid: 8602715].
11 Garber AM, Browner WS, Hulley SB. Guidelines for using serum cholesterol, high-density lipoprotein cholesterol, and triglyceride levels as screening tests for preventing coronary heart disease in adults. Ann Intern Med. 1996;124:515-517. [pmid: 8602714].
12 Logan AG. Lowering the blood total cholesterol level to prevent coronary heart disease. Canadian Task Force on the Periodic Health Examination. Canadian Guide to Clinical Preventive Health Care. 1994:650-69. [pmcid: 368383].