# Recommendations of Others

Routine measurement of nonfasting TC and HDL every 5 years is recommended by the National Cholesterol Education Program's Adult Treatment Panel II (ATP II), sponsored by the National Institutes of Health (6), and endorsed by the American Heart Association (7) and the American College of Obstetricians and Gynecologists (8). The American College of Physicians and American Academy of Family Physicians suggest periodic cholesterol measurement in men aged 35 to 65 years and in women aged 45 to 65 years (9,10,11). In 1994, the Canadian Task Force on Preventive Health Care recommended selective case-finding in men aged 30 to 59 years, rather than routine screening (12). The ATP II and the Canadian Task Force recommendations are currently being updated.