# Discussion

The clearest benefit of lipid screening is identifying individuals whose near-term risk of coronary heart disease is sufficiently high to justify drug therapy or other intensive lifestyle interventions to lower cholesterol. Screening men older than age 35 years and women older than age 45 years will identify nearly all individuals whose risk of coronary heart disease is as high as that of the subjects in the existing primary prevention trials. In a population with a 1% risk of coronary heart disease per year, drug treatment of 67 people for 5 years is required to prevent one coronary heart disease event. Most younger people have a substantially lower risk, unless they have other important risk factors for coronary heart disease or familial hyperlipidemia.

The primary goal of screening younger people is to promote lifestyle changes, which may provide long-term benefits later in life. The average effect of diet interventions is small, however, and screening is not necessary to advise young adults about the benefits of a healthy diet and regular exercise. Although universal screening may detect some patients with familial hyperlipidemia earlier than selective screening, whether this will lead to important reductions in coronary events is not known.