# Scientific Evidence

## Epidemiology and Clinical Consequences

Consistent evidence from long-term, prospective studies indicates that high levels of TC and LDL-C and low levels of HDL-C are important risk factors for coronary heart disease, the leading cause of mortality and morbidity in the United States. The risk for coronary heart disease increases with increasing levels of TC and LDL-C, and declining levels of HDL-C, in a continuous and graded fashion with no clear threshold of risk. According to National Center for Health Statistics data from 1988 to 1994, 17.5% of men and 20% of women aged 20 to 74 years had high levels of TC (240 mg/dL or greater).

## Accuracy and Reliability of Screening Test

TC, LDL-C, and HDL-C are independent predictors of coronary heart disease risk, but considering other risk factors (age, diabetes, smoking, blood pressure) in addition to lipid levels markedly improves the estimation of risk. The ratios of TC to HDL-C (TC/HDL-C) or LDL-C to HDL-C (LDL-C/HDL-C) classify risk better than TC alone.

TC and HDL-C can be measured accurately on nonfasting venous or capillary blood samples, but LDL-C requires fasting samples for accurate measurement. At least two measurements are necessary to ensure that true values are within 10% of the mean of the measurements.

## Effectiveness of Early Detection

In four large primary prevention trials, cholesterol-lowering drug treatment for 5 to 7 years decreased risk of coronary heart disease events approximately 30% in people with high TC or average cholesterol and low HDL-C. In the one trial that included women, treatment appeared to be as effective in postmenopausal women as in men. The average benefit of treating abnormal lipids in women, however, may be smaller than in men of similar ages because of their lower rates of heart disease. Although trials have enrolled few people younger than age 45 years or older than age 65 years, the USPSTF concluded that the benefits of treatment could be generalized to older and younger people whose underlying risk of coronary heart disease is comparable to or greater than that of subjects in the existing trials (annual incidence of coronary heart disease 0.6% to 1.5% per year).

The only trials examining diet with coronary heart disease outcomes have modified diet in conjunction with interventions on other risk factors, in patients with heart disease, or using atypical institutional diets. Reducing dietary saturated fat and weight loss can lower TC and LDL-C as much as 10% to 20% in some individuals, but the average effect of diet interventions in outpatients is relatively modest (2% to 6% reduction in TC). Lipid screening does not clearly improve the effectiveness of routine diet interventions.

## Potential Adverse Effects of Screening

Studies of adverse effects of screening are limited but have not found adverse psychological effects (i.e., labeling) in patients identified with abnormal lipids. Screening could subject some low-risk people to the inconvenience and expense of treatments that may offer only minimal benefits.