# References and Notes

1 U.S. Preventive Services Task Force. Guide to clinical preventive services, 2nd ed. Washington, DC: Office of Disease Prevention and Health Promotion, U.S. Government Printing Office, 1996.1.
2 Helfand M, Mahon SM, Eden KB, Frame PS, Orleans CT. Screening for skin cancer. Am J Prev Med. 2001:47-58. [pmid: 11306232]. [pmcid: 87677].
3 Helfand M, Mahon S, Eden K. Screening for skin cancer. Systematic evidence review. Pub. No. AHRQ01-S002. Rockville, MD: Agency for Healthcare Research and Quality, 2001.
4 Feightner JW. Prevention of skin cancer. Canadian Task Force on the Periodic Health Examination. 1994:850-9.
5 American Cancer Society. Melanoma: detection and symptoms. Available at: http://www3.cancer.org/cancerinfo/. Accessed February 15, 2001.
6 Ferrini RL, Perlman M, and Hill L. American College of Preventive Medicine policy statement: screening for skin cancer. Am J Prev Med. 1998;14:80-82. [pmid: 9476841].
7 American College of Obstetricians and Gynecologists Committee on Gynecologic Practice. Primary and preventive care: periodic assessments. Committee opinion no. 246. Washington, DC: American College of Obstetricians and Gynecologists, Dec 2000.
8 NIH Consensus Development Panel on Early Melanoma. Diagnosis and treatment of early melanoma. JAMA. 1992;268:1314-19. [pmid: 1507379].
9 National Health and Medical Research Council. Guidelines for preventive interventions in primary health care: cardiovascular disease and cancer. Report of the Assessment of Preventive Activities in the Health Care System Initiative. Canberra, Australia: National Health and Medical Research Council, Commonwealth of Australia, Dec 1996.