# Discussion

Periodic total-body skin examination can increase the detection of thin (earlier stage) melanoma; however, controlled studies are needed to determine whether early detection would actually have an important effect on mortality. Additional questions remain about the ability of primary care clinicians to perform adequate examinations in the context of usual care. Studies of skin health behaviors and studies of factors associated with advanced melanoma suggest that older persons are at high risk and are unlikely to benefit from existing skin cancer prevention efforts such as public education and clinician education efforts regarding sun avoidance and/or sun protection. While it is unproven, skin cancer screening (using a risk assessment strategy with examination or referral of high-risk patients) is the most promising strategy for addressing the excess burden of disease in older persons. Since most elderly individuals consult a clinician at least yearly, case finding by clinicians focusing on the elderly may reach vulnerable individuals who may not benefit from other approaches.