# Recommendations of Others

The Canadian Task Force on Preventive Health Care concluded that the evidence was insufficient to recommend for or against skin cancer screening for the general population, but suggests that regular total-body skin examination may be prudent for a subgroup of very high-risk individuals (4). The American Cancer Society recommends skin examination as part of a cancer-related checkup every 3 years for people aged between 20 and 40, and on a yearly basis for anyone aged >40 (5). The American College of Preventive Medicine recommends total-body skin examination in high-risk individuals, including those with a family or personal history of skin cancer, predisposing phenotypic characteristics, and increased occupational or recreational exposure to sunlight, or clinical evidence of precursor lesions (e.g., dysplastic or congenital nevi), but does not recommend routine screening (6). The American College of Obstetricians and Gynecologists recommends yearly, or as appropriate, skin examination of women aged >13 based on risk factors (increased recreational or occupational exposure to sunlight; family or personal history of skin cancer; clinical evidence of precursor lesions) (7). A National Institutes of Health (NIH) Consensus Panel recommends screening for melanoma as part of routine primary care (8). The Australian National Health and Medical Research Council does not recommend mass screening or screening of high-risk people for melanoma (9). All of these organizations advise public or patient education to change behaviors that may increase the risk of skin cancer, including sun avoidance, sun protection, and skin self-examination.