# Scientific Evidence

## Epidemiology and Clinical Consequences

In the United States, the lifetime risk of dying of melanoma is 0.36% among men and 0.21% among women. Between 1973 and 1995 the incidence of melanoma increased from 5.7 per 100,000 to 13.3 per 100,000. Although primary prevention efforts have focused on young people, the elderly (especially elderly men) bear a disproportionate burden of morbidity and mortality from melanoma and nonmelanoma skin cancer. Men aged >65 (5.2% of the U.S. population) are diagnosed with 22% of the new cases of malignant melanoma each year; women aged >65 (7.4% of the population) are diagnosed with 14% of new cases. In the elderly, melanoma tends to be diagnosed at a later stage and is more likely to be lethal than it is in the general population.

Basal cell and squamous cell carcinomas, in contrast to melanoma, are very common, especially in the elderly. However, they cause limited morbidity or mortality even in the absence of formal screening.

## Accuracy and Reliability of Screening Test

The most commonly advocated screening test for skin cancer is a total-body skin examination by a clinician. Although data are sparse and based entirely on studies of volunteer patients, the sensitivity and specificity of a total-body skin examination performed by a dermatologist for the diagnosis of skin cancer are reported to be high, 94% and 98%, respectively. Data regarding the accuracy of the total-body skin examination performed by nonspecialists are few, but suggest slightly lower sensitivity and much lower specificity than examinations performed by dermatologists.

Another screening strategy is to use a questionnaire or interview to assess risk factors such as family history and sun exposure and refer only high-risk patients for total-body skin examinations. Clinicians and patients can reliably measure some risk factors for melanoma, but the validity of formal risk-assessment tools to screen unselected patients in primary care has not been established.

## Yield of Screening Test

While dependent on the population screened, rates of suspected melanoma in mass screening, case finding, and population-based screening range from 0 to 9 per 100 people screened, with the most common findings between 1 and 3 per 100. Rates of confirmed melanoma and melanoma in situ are commonly in the range of 1 to 4 per 1000 people screened. One to five percent of screened patients are confirmed to have nonmelanoma skin cancer.

## Effectiveness of Early Detection

There are no randomized trials or case-control studies that directly examine whether screening by clinicians is associated with improved clinical outcomes such as reduced morbidity or mortality from skin cancer. The possibility that earlier treatment as a result of screening improves health outcomes must rely on indirect evidence.

Screening consistently identifies melanomas that are, on average, thinner (i.e., at an earlier stage) than those found during usual care. It is not known if this stage shift leads to decreased morbidity or mortality. A case-control study in which skin self-examination was associated with a lower incidence of lethal melanoma provides indirect evidence that the shift to earlier stages found in screening may be associated with better clinical outcomes. Evidence from studies of the consequences of delay in diagnosis is inconsistent.

Even without formal screening programs, mortality from basal cell and squamous cell carcinoma is low compared to mortality from melanoma, but early detection and treatment may reduce morbidity and disfigurement from these cancers. No studies were found that evaluated whether screening improves the outcomes of these cancers.

## Potential Adverse Effects of Screening

There are no serious risks from total-body skin examination but examination may be embarrassing to some patients and inconvenient in some settings. Screening could result in unnecessary treatment, either due to misdiagnosis or to detection of lesions that might not have caused clinical consequences. Screening also detects large numbers of benign skin conditions, which are very common in the elderly and could lead to additional biopsies and unnecessary or expensive procedures.