# Summary of Recommendations

- The U.S. Preventive Services Task Force (USPSTF) concludes that the evidence is insufficient to recommend for or against routine screening for skin cancer using a total-body skin examination for the early detection of cutaneous melanoma, basal cell cancer, or squamous cell skin cancer (I recommendation).

Evidence is lacking that skin examination by clinicians is effective in reducing mortality or morbidity from skin cancer. The USPSTF could not determine the benefits and harms of periodic skin examination. (See Clinical Considerations for discussion of selected populations at high risk.)

Other strategies to prevent skin cancer, such as counseling to reduce risky health behaviors and performance of skin self-examination, will be addressed in a separate recommendation.