# References

1 U.S. Preventive Services Task Force. Guide to Clinical Preventive Services, second ed., Washington, DC: Office of Disease Prevention and Health Promotion 1996 190016
2 Nelson HD, Helfand M, Woolf SH, et al. Screening for postmenopausal osteoporosis: A review of the evidence for the US Preventive Services Task Force. Ann Intern Med. 2002;137:529-41. (Available on the AHRQ Web site at http://www.preventiveservices.ahrq.gov). [pmid: 12230356].
3 Nelson HD, Helfand M. Screening for Postmenopausal Osteoporosis. Systematic Evidence Review No. 17 (Prepared by the Oregon Health & Science University Evidence-based Practice Center under Contract No. 290-97-0018.), Rockville, , MD: . Agency for Healthcare Research and Quality, Research and Quality 2002. (Available on the AHRQ Web site at: http://www.ahrq.gov/clinic/serfiles.htm) 321147
4 Cadarette SM, Jaglal SB, Kreiger N, et al. Development and validation of the Osteoporosis Risk Assessment Instrument to facilitate selection of women for bone densitometry. Can Med Assoc J. 2000;162:1289-94. [pmid: 10813010].
5 Cadarette SM, Jaglal SB, Murray T, et al. Evaluation of decision rules for referring women for bone densitometry by dual-energy x-ray absorptiometry. JAMA. 2001;286(1):57-63. [pmid: 11434827]. [pmcid: 99649].
6 Melton LJ 3rd, Kan SH, Frye MA, et al. Epidemiology of vertebral fractures in women. Am J Epidemiol. 1989;129:1000-11. [pmid: 2784934].
7 Barrett JA, Baron JA, Karagas MR, et al. Fracture risk in the US Medicare population. J Clin Epidemiol. 1999;52:243-9. [pmid: 10210242].
8 Kanis JA. Assessment of fracture risk and its application to screening for postmenopausal osteoporosis: synopsis of a WHO report. Osteoporos Int. 1994;4:368-81. [pmid: 7696835]. [pmcid: 368704].
9 Melton LJ 3rd. How many women have osteoporosis now? J. Bone Miner Res. 1995;10:175-7. [pmcid: 326124].
10 Looker AC, Wahner HW, Dunn WL, et al. Updated data on proximal femur bone mineral levels of US adults. Osteoporos Int. 1998;8:468-89. [pmid: 9850356]. [pmcid: 131044].
11 Lydick E, Cook K, Turpin J, et al. Development and validation of a simple questionnaire to facilitate identification of women likely to have low bone density. Am J Manag Care. 1998;4:37-48. [pmid: 10179905]. [pmcid: 324586].
12 Siris ES, Miller PD, Barrett-Connor E, et al. Identification and fracture outcomes of undiagnosed low bone mineral density in postmenopausal women: Results from the National Osteoporosis Risk Assessment. JAMA. 2001;286:2815-22. [pmid: 11735756].
13 Nelson HD, Helfand M. Hormone Replacement Therapy and Osteoporosis. Systematic Evidence Review No 12 (Prepared by the Oregon Health & Science University Evidence-based Practice Center under Contract No. 290-97-0018.), Rockville, , MD: . Agency for Healthcare Research and Quality 2002. (Available only on the AHRQ Web site at www.ahrq.gov/clinic/serfiles.htm)
14 Burger H, de Laet CE, Weel AE, et al. Added value of bone mineral density in hip fracture risk scores. Bone. 1999;25:369-74. [pmid: 10495142]. [pmcid: 380813].
15 Bouxsein ML, Radloff SE. Quantitative ultrasound of the calcaneus reflects the mechanical properties of calcaneal trabecular bone. J Bone Miner Res. 1997;12:839-46. [pmid: 9144351].
16 Cranney A, Wells G, Willan A, et al. Meta-analysis of alendronate for the treatment of postmenopausal women. Endocr Rev. 2002;23:517-23. [pmid: 12202466]. [pmcid: 268686].
17 Black DM, Cummings SR, Karpf DB, et al. Randomised trial of effect of alendronate on risk of fracture in women with existing vertebral fractures. Fracture Intervention Trial Research Group. Lancet. 1996:1535-41. [pmid: 8950879]. [pmcid: 39975].
18 Adami S, Passeri M, Ortolani S, et al. Effects of oral alendronate and intranasal salmon calcitonin on bone mass and biochemical markers of bone turnover in postmenopausal women with osteoporosis. Bone. 1995:383-90. [pmid: 8573412]. [pmcid: 306687].
19 Bone HG, Downs RW Jr, Tucci JR, et al. Dose-response relationships for alendronate treatment in osteoporotic elderly women. Alendronate Elderly Osteoporosis Study Centers. J Clin Endocrinol Metab. 1997:265-74. [pmid: 8989272]. [pmcid: 19310].
20 Chesnut CH, 3rd, McClung MR, Ensrud KE, et al. Alendronate treatment of the postmenopausal osteoporotic woman: effect of multiple dosages on bone mass and bone remodeling. Am J Med. 1995:144-52. [pmid: 7625419]. [pmcid: 176566].
21 Hosking D, Chilvers CE, Christiansen C, et al. Prevention of bone loss with alendronate in postmenopausal women under 60 years of age. Early Postmenopausal Intervention Cohort Study Group. NEJM. 1998:485-92. [pmid: 9443925]. [pmcid: 35105].
22 Liberman UA, Weiss SR, Broll J, et al. Effect of oral alendronate on bone mineral density and the incidence of fractures in postmenopausal osteoporosis. The Alendronate Phase III Osteoporosis Treatment Study Group. NEJM. 1995:1437-43. [pmid: 7477143]. [pmcid: 375280].
23 McClung M, Clemmesen B, Daifotis A, et al. Alendronate prevents postmenopausal bone loss in women without osteoporosis. A double-blind, randomized, controlled trial. Alendronate Osteoporosis Prevention Study Group. Ann Intern Med. 1998:253-61. [pmid: 9471927]. [pmcid: 18192].
24 Greenspan SL, Parker RA, Ferguson L, et al. Early changes in biochemical markers of bone turnover predict the long-term response to alendronate therapy in representative elderly women: A randomized clinical trial. J Bone Miner Res. 1998;13:1431-8. [pmid: 9738515]. [pmcid: 341087].
25 Pols HA, Felsenberg D, Hanley DA, et al. Multinational, placebo-controlled, randomized trial of the effects of alendronate on bone density and fracture risk in postmenopausal women with low bone mass: results of the FOSIT study. Foxamax International Trial Study Group. Osteo Intern. 1999:461-8. [pmcid: 83904].
26 Cummings SR, Black DM, Thompson DE, et al. Effect of alendronate on risk of fracture in women with low bone density but without vertebral fractures: results from the Fracture Intervention Trial. JAMA. 1998:2077-82. [pmid: 9875874]. [pmcid: 19255].
27 Bonnick S, Rosen C, Mako B, et al. Alendronate vs calcium for treatment of osteoporosis in postmenopausal women. Bone. 1998. [pmcid: 325579].
28 McClung M, Geusens P, Miller P, et al. Effect of risedronate on the risk of hip fracture in elderly women. NEJM. 2001;344:333-40. [pmid: 11172164].
29 Lufkin EG, Whitaker MD, Nickelsen T, et al. Treatment of established postmenopausal osteoporosis with raloxifene: a randomized trial. J Bone Miner Res. 1998;13:1747-54. [pmid: 9797484]. [pmcid: 341109].
30 Cummings SR, Black DM, Thompson DE. Effect of alendronate on risk of fracture in women with low bone density but without vertebral fractures: results from the Fracture Intervention Trial. JAMA. 1998;280:2077-82. [pmid: 9875874].
31 National Osteoporosis Foundation. Physician's guide to prevention and treatment of osteoporosis, Washington, DC: NOF; 1999. Available at: http://www.nof.org/physguide. Accessed July 29, 2002
32 American Association of Clinical Endocrinologists. 2001 Medical Guidelines for Clinical Practice for the Prevention and Management of Postmenopausal Osteoporosis. Available at: http://www.aace.com/clin/guidelines/osteoporosis2001.pdf. Accessed February 27, 2002.
33 Osteoporosis Prevention, Diagnosis, and Therapy. NIH Consensus Statement Online 2000. March 27-29; 17(1): 1-36. Available at: http://odp.od.nih.gov/consensus/cons/111/111_statement.htm. Accessed February 27, 2002.