# Reprints

Available online through the National Guideline Clearinghouse™ (http://www.guideline.gov); reprints can be obtained from the AHRQ Publications Clearinghouse (call 1-800-358-9295; E-mail ahrqpubs@ahrq.gov).

Internet Citation:

U.S. Preventive Services Task Force. Screening for Osteoporosis in Postmenopausal Women. September 2002. Originally in Annals of Internal Medicine 2002;137:526-8. Agency for Healthcare Research and Quality, Rockville, MD. http://www.ahrq.gov/clinic/3rduspstf/osteoporosis/osteorr.htm