# Recommendations of Others

In 1998, the National Osteoporosis Foundation, in collaboration with other professional organizations, issued screening guidelines recommending bone density testing for all women aged 65 or older and younger postmenopausal women who have had a fracture or who have one or more risk factors for osteoporosis.^31^ Collaborating groups included the American Academy of Orthopaedic Surgeons, the American College of Obstetricians and Gynecologists, the American Geriatrics Society, the American College of Radiology, the American College of Rheumatology, the American Academy of Physical Medicine and Rehabilitation, the American Association of Clinical Endocrinologists, the Endocrine Society, and the American Society of Bone and Mineral Research. The American Association of Clinical Endocrinologists released revised guidelines in 2001.^32^ A 2000 Consensus Development Conference sponsored by the U.S. National Institutes of Health concluded that the value of universal osteoporosis screening was not yet established.^33^ The conference panel recommended an individualized approach to screening, noting that bone density measurement is appropriate when it will aid the patient's decision to institute treatment. The Canadian Task Force on Preventive Health Care is currently revising its recommendations on screening for osteoporosis.