# Behavioral Counseling in Primary Care to Promote Physical Activity: Recommendations and Rationale

This statement summarizes the U.S. Preventive Services Task Force (USPSTF) recommendations on counseling by primary care physicians to promote physical activity and the supporting scientific evidence, and it updates the 1996 recommendations contained in the Guide to Clinical Preventive Services, second edition.^1^ Explanations of the ratings and of the strength of overall evidence are given in Appendix A and Appendix B, respectively. The complete information on which this statement is based, including evidence tables and references, is available in the accompanying article "Counseling by Clinicians: Does It Improve Physical Activity?"^2^ which can be obtained through the USPSTF Web site (http://www.preventiveservices.ahrq.gov) and in print through the AHRQ Publications Clearinghouse (call 1-800-358-9295 or E-mail ahrqpubs@ahrq.gov).

## Contents

Summary of Recommendation

Clinical Considerations

Scientific Evidence

Discussion

Recommendations of Others

USPSTF Recommendations and Ratings

USPSTF Strength of Overall Evidence

Acknowledgments

References