# Newborn Hearing Screening: Recommendations and Rationale

This statement summarizes the third U.S. Preventive Services Task Force (USPSTF) recommendations on newborn hearing screening and the supporting scientific evidence, and it updates the 1995 recommendations contained in the Guide to Clinical Preventive Services second edition.^1^ Explanations of the ratings and of the strength of overall evidence are given in Appendix A and Appendix B, respectively. The complete information on which this statement is based, including evidence tables and references, is available in the article, "Universal Newborn Hearing Screening: A Summary of the Evidence"^2^ and in the Systematic Evidence Review ^3^

## Contents

Summary of Recommendation

Clinical Considerations

Scientific Evidence

Recommendations of Others

Acknowledgements

Appendix A

Appendix B

References