# Routine Vitamin Supplementation to Prevent Cancer and Cardiovascular Disease

This statement summarizes the current U.S. Preventive Services Task Force (USPSTF) recommendation on routine vitamin supplementation to prevent cancer and cardiovascular disease , and updates the 1996 recommendation contained in the Guide to Clinical Preventive Services, Second Edition^1^.

## Contents

Summary of Recommendations

Clinical Considerations

Scientific Evidence

Discussion

Recommendations of Others

Task Force Ratings

Members of the Task Force

References