# Screening for Suicide Risk

This statement summarizes the current U.S. Preventive Services Task Force (USPSTF) recommendations on screening for suicide risk and the supporting scientific evidence, and it updates the 1996 recommendations contained in the Guide to Clinical Preventive Services, Second Edition.^1^

## Contents

Summary of Recommendation

Clinical Considerations

Discussion

Recommendations of Others

Task Force Ratings

Members of the Task Force

References