# Screening for Prostate Cancer

This statement summarizes the current U.S. Preventive Services Task Force (USPSTF) recommendation on screening for prostate cancer , and updates the 1996 recommendation contained in the Guide to Clinical Preventive Services, Second Edition^1^.

## Contents

Summary of Recommendations

Clinical Considerations

Scientific Evidence

Recommendations of Others

Task Force Ratings

Members of the Task Force

References