# Screening for Obesity in Adults

This statement summarizes the U.S. Preventive Services Task Force (USPSTF) recommendations on screening for obesity in adults based on the USPSTF's examination of evidence specific to obesity and overweight in adults. It updates the 1996 recommendations contained in the Guide to Clinical Preventive Service, Second Edition^1^.

## Contents

Summary of Recommendations

Clinical Considerations

Scientific Evidence

Recommendations of Others

Task Force Ratings

Members of the Task Force

References