# Screening for High Blood Pressure

This statement summarizes the current U.S. Preventive Services Task Force (USPSTF) recommendation on screening for high blood pressure, and updates the 1996 recommendation contained in the Guide to Clinical Preventive Services, Second Edition^1^.

## Contents

Summary of Recommendation

Clinical Considerations

Scientific Evidence

Recommendations of Others

Task Force Ratings

Members of the Task Force

References