# Behavioral Counseling in Primary Care to Promote a Healthy Diet

This statement summarizes the U.S. Preventive Services Task Force (USPSTF) recommendations on counseling to promote a healthy diet in primary care patients and the supporting evidence, and it updates the 1996 recommendations contained in the Guide to Clinical Preventive Services, 2nd edition.^1^ Explanations of the ratings and of the strength of overall evidence are given in Appendix A and Appendix B, respectively. The complete information on which this statement is based, including evidence tables and references, is available in the Systematic Evidence Review^2^ on this topic, which can be obtained through the USPSTF Web site (www.preventiveservices.ahrq.gov) and in print through the AHRQ Publications Clearinghouse (call 1‐800‐358‐9295 or E‐mail ahrqpubs@ahrq.gov).

To address whether to recommend counseling to promote a healthy diet among primary care patients, the USPSTF reviewed the evidence on nutritional and behavioral counseling by a variety of practitioners (physicians, nurses, nutritionists, dietitians, health educators) and in a variety of clinical settings (e.g., primary care practices, specialty clinics). In updating its recommendations, the USPSTF did not re‐evaluate the benefits of a healthy diet, which are detailed in many other reports. Instead, it focused on new controlled studies of the efficacy of counseling for changing dietary behavior in patients similar to those found in primary care practices.The review did not include studies of dietary interventions for specific chronic illnesses (e.g., heart disease, diabetes, renal failure) but included studies enrolling patients with common risk factors such as elevated cholesterol, hypertension, obesity, or family history of heart disease. Counseling interventions with a primary focus on weight loss, weight management, and/or the treatment of obesity are covered in a separate review^3^ and are outside the scope of this recommendation. Studies of diet interventions focusing on lowering cholesterol levels in patients with elevated cholesterol or other lipid abnormalities are addressed in a separate USPSTF report entitled Screening for Lipid Disorders in Adults.^4^ Studies of breastfeeding will also be addressed in a future USPSTF report. All published reports are available on the USPSTF Web site at: www.preventiveservices.ahrq.gov.

## Contents

Summary of Recommendations

Clinical Considerations

Scientific Evidence

Discussion

Recommendations of Others

Appendix A

Appendix B

Members of the Task Force

References