# Screening for Type 2 Diabetes Mellitus in Adults

This statement summarizes the current U.S. Preventive Services Task Force (USPSTF) recommendation on screening for type 2 diabetes mellitus in adults, and updates the 1996 recommendation contained in the Guide to Clinical Preventive Services, Second Edition^1^.

## Contents

Summary of Recommendation

Clinical Considerations

Scientific Evidence

Recommendations of Others

Task Force Ratings

Members of the Task Force

References