# Prevention of Dental Caries in Preschool Children

This statement summarizes the USPSTF recommendations on the primary care clinician's role in the prevention of dental disease among preschool children based on the USPSTF's examination of evidence specific to dental disease in young children. It updates the 1996 recommendations in the Guide to Clinical Preventive Services, Second Edition.^1^

## Contents

Summary of Recommendation

Clinical Considerations

Discussion

Recommendations of Others

Task Force Ratings

Members of the Task Force

References