# Screening for Cervical Cancer

This statement summarizes the current U.S. Preventive Services Task Force (USPSTF) recommendations on screening for cervical cancer and the supporting scientific evidence, and updates the 1996 recommendations contained in the Guide to Clinical Preventive Services, Second Edition. ^1^ Explanations of the ratings and of the strength of overall evidence are given in Appendix A (http://www.ahrq.gov/clinic/3rduspstf/cervcan/cervcanrr2.htm#appendixa) and Appendix B (http://www.ahrq.gov/clinic/3rduspstf/cervcan/cervcanrr2.htm#appendixb), respectively. The complete information on which this statement is based, including evidence tables and references, is available in the Systematic Evidence Review "Screening for Cervical Cancer,"^2^ available through the USPSTF Web site (www.preventiveservices.ahrq.gov) and through the National Guideline Clearinghouse™ (http://www.guideline.gov). The summary of the evidence and the recommendation statement are also available in print through the AHRQ Publications Clearinghouse (call 1‐800‐358‐9295 or E‐mail ahrqpubs@ahrq.gov).

## Contents

Summary of Recommendations

Clinical Considerations

Scientific Evidence

Appendix A. USPSTF Recommendations and Ratings

Appendix B. USPSTF Strength of Overall Evidence

Members of the Task Force

References