# Behavioral Interventions To Promote Breastfeeding

This statement summarizes the current U.S. Preventive Services Task Force (USPSTF) recommendation on counseling to promote breastfeeding, a new topic for the USPSTF. The complete information on which this statement is based, including evidence tables and references, is available in the Evidence Review (http://www.ahrq.gov/clinic/3rduspstf/brstfeed/brfeedsum.htm) ^1^.

## Contents

Summary of Recommendation

Clinical Considerations

Scientific Evidence

Discussion

Recommendations of Others

Task Force Ratings

Members of the Task Force

References