# Aspirin for the Primary Prevention of Cardiovascular Events

This statement summarizes the current U.S. Preventive Services Task Force (USPSTF) recommendation on aspirin for the primary prevention of cardiovascular events and the supporting scientific evidence, and updates the 1995 recommendation contained in the Guide to Clinical Preventive Services, Second Edition^1^.

## Contents

Summary of Recommendation

Clinical Considerations

Scientific Evidence

Recommendations of Others

Task Force Ratings

Members of the Task Force

References