# Screening for Depression: Recommendations and Rationale

This statement summarizes the current U.S. Preventive Services Task Force (USPSTF) recommendations for screening for depression and the supporting scientific evidence and updates the 1996 USPSTF recommendations on this topic. At that time, the USPSTF concluded that there was insufficient evidence to recommend for or against routine use of standardized questionnaires to screen for depression in primary care patients. The complete information on which this statement is based, including evidence tables and references, is available in the accompanying article, "Screening for Depression: A Summary of the Evidence for the U.S. Preventive Services Task Force" and in the Systematic Evidence Review on this topic (1), which can be obtained through the USPSTF Web site (http://www.ahrq.gov/clinic/uspstfix.htm) and in print through the AHRQ Publications Clearinghouse (call 1-800-358-9295; E-mail ahrqpubs@ahrq.gov).

## Contents

Summary of Recommendations

Clinical Considerations

Scientific Evidence

Recommendations of Others

USPSTF Recommendations and Ratings

USPSTF Strength of Overall Evidence

Acknowledgments

References