# Screening for Colorectal Cancer: Recommendations and Rationale

This statement summarizes the current U.S. Preventive Services Task Force (USPSTF) recommendations on screening for colorectal cancer and the supporting scientific evidence, and it updates the 1996 recommendations contained in the Guide to Clinical Preventive Services, 2nd edition. At that time, the USPSTF recommended screening for colorectal cancer with annual fecal occult blood testing (FOBT), periodic sigmoidoscopy, or the combination of FOBT and sigmoidoscopy but concluded that the evidence was insufficient to recommend for or against colonoscopy or barium enema.

Select for explanations of the current ratings and of the strength of overall evidence. The complete information on which this statement is based, including evidence tables and references, is available in the summary of the evidence (http://colosum.htm)^1^ and the Systematic Evidence Review^2^ on this topic, which can be obtained through the USPSTF Web site (http://www.preventiveservices.ahrq.gov) and through the National Guideline Clearinghouse™ (http://www.guideline.gov/summary/summary.aspx?doc_id=3285&nbr=2511). It is available in print through the AHRQ Publications Clearinghouse (phone, 800-358-9295; E-mail, ahrqpubs@ahrq.gov).

## Contents

Summary of Recommendation

Clinical Considerations

Scientific Evidence

Recommendations of Others

USPSTF Recommendations and Ratings

USPSTF Strength of Overall Evidence

Acknowledgments

References