# Chemoprevention of Breast Cancer: Recommendations and Rationale

This statement summarizes the U.S. Preventive Services Task Force (USPSTF) recommendations for the chemoprevention of breast cancer and the supporting scientific evidence. The complete information on which this statement is based, including evidence tables and references, is available in the accompanying article "Chemoprevention of Breast Cancer: A Summary of the Evidence (http://www.ahrq.gov/clinic/3rduspstf/breastchemo/brchemsum.htm)"^1^ and in the summary of the evidence and Systematic Evidence Review^2^ on this topic, available through the USPSTF Web site (http://www.preventiveservices.ahrq.gov) and the National Guideline Clearinghouse™ (http://www.guideline.gov/summary/summary.aspx?doc_id=3229&nbr=2455). It is available in print through the Agency for Heathcare Research and Quality's Publications Clearinghouse (call 1-800-358-9295 or E-mail ahrqpubs@ahrq.gov).

## Contents

Summary of Recommendations

Clinical Considerations

Scientific Evidence

Recommendations of Others

USPSTF Recommendations and Ratings

USPSTF Strength of Overall Evidence

Acknowledgments

References