# Appendices

Appendix A Task Force Ratings

Appendix B Reviewers