# Appendix B Reviewers

Listed below are nearly 700 Federal and non-Federal experts who reviewed Task Force draft background papers, chapters, and recommendations during their various stages of preparation. Many of these reviews were arranged by the liaisons to the Task Force (listed in the Acknowledgments) from primary care specialty societies, including the American Academy of Family Physicians (AAFP), American Academy of Pediatrics (AAP), American College of Obstetricians and Gynecologists, and American College of Physicians, and from Public Health Service (PHS) agencies, and by other professional organizations. We gratefully acknowledge the contribution of many other unnamed reviewers who provided helpful comments through various PHS agencies, professional societies, and voluntary organizations. Staff from the Food and Drug Administration (FDA) also reviewed draft chapters, background papers, and recommendations for the Task Force. Their review of these documents does not necessarily imply FDA approval of specific products for the indications described in the Task Force recommendations.

It should be emphasized that while reviewer comments and suggestions were of substantial assistance and are gratefully acknowledged, the Task Force is solely responsible for the final recommendations. Service as a reviewer does not necessarily reflect endorsement of any or all of the Task Force recommendations.

- Rhoda Abrams, M.B.A.
- Health Resources and Services Administration
- Bethesda, MD

- Harold P. Adams, Jr., M.D.
- University of Iowa
- Iowa City, IA

- M.J. Adams, M.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Nancy E. Adler, Ph.D.
- University of California at San Francisco
- San Francisco, CA

- David A. Ahlquist, M.D.
- Mayo Clinic
- Rochester, MN

- Dennis J. Ahnen, M.D., F.A.C.G.
- University of Colorado
- Denver, CO

- Beth Alexander, M.D., M.S.
- Michigan State University/AAFP
- East Lansing, MI

- John Allen, Ph.D.
- National Institutes of Health
- Rockville, MD

- Michael Allerton, M.S.
- Kaiser Permanente Medical Care Program
- Oakland, CA

- Elaine J. Alpert, M.D., M.P.H.
- Boston University
- Boston, MA

- Miriam J. Alter, Ph.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Tom Anan, M.D.
- Providence Hospital/AAFP
- Novi, MI

- Robert Anda, M.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Jay R. Anderson, D.M.D., M.H.S.A.
- Health Resources and Services Administration
- Bethesda, MD

- Reubin Andres, M.D.
- National Institutes of Health
- Baltimore, MD

- James C. Anthony, Ph.D.
- The Johns Hopkins University
- Baltimore, MD

- Richard Atkinson, M.D.
- University of Wisconsin at Madison
- Madison, WI

- N. Burton Attico, M.D., M.P.H.
- Indian Health Service
- Phoenix, AZ

- Thomas F. Babor, Ph.D.
- University of Connecticut
- Farmington, CT

- Ronald Bachman, M.D.
- Kaiser Permanente Medical Care Program
- Oakland, CA

- Christine Bachrach, Ph.D.
- National Institutes of Health
- Bethesda, MD

- Shirley Bagley
- National Institutes of Health
- Bethesda, MD

- David R. Baines, M.D., F.A.A.F.P.
- American Academy of Family Physicians
- St. Maries, ID

- Ray Baker, M.D.
- Ray Baker, M.D., Inc.
- White Rock, British Columbia

- Susan S. Baker, M.D., Ph.D.
- Medical University of South Carolina
- Charleston, SC

- Albert Barrocas, M.D.
- Pendleton Memorial Methodist Hospital
- New Orleans, LA

- Michael J. Barry, M.D.
- Massachusetts General Hospital
- Boston, MA

- Joel L. Bass, M.D.
- MetroWest Medical Center
- Framingham, MA

- David M. Baughan, M.D.
- University of California at San Diego/AAFP
- La Jolla, CA

- David D. Bayse, Ph.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Roberta K. Beach, M.D.
- Westside Health Center/AAP
- Denver, CO

- John W. Beasley, M.D.
- University of Wisconsin at Madison/AAFP
- Madison, WI

- Marie-Dominique Beaulieu, M.D.,M.Sc., F.C.F.P.
- University of Montreal
- Montreal, Quebec

- David V. Becker, M.D.
- New York Hospital-Cornell Medical Center
- New York, NY

- Myron L. Belfer, M.D.
- Substance Abuse and Mental Health Services Administration
- Rockville, MD

- David Bellinger, M.D.
- Children's Hospital Medical Center
- Boston, MA

- Beryl Benacerraf, M.D.
- Diagnostic Ultrasound Associates, P.C.
- Boston, MA

- Birgitte H. Bendixen, M.D., Ph.D.
- University of Iowa
- Iowa City, IA

- Heinz Berendes, M.D.
- National Institutes of Health
- Rockville, MD

- Cynthia J. Berg, M.D., M.P.H.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Alan L. Berman, Ph.D.
- Washington Psychological Center
- Washington, DC

- S. Thomas Bigos, M.D.
- Maine Medical Center
- Portland, ME

- William F. Bina, III, M.D., M.P.H.
- Family Practice Residency Program/AAFP
- Macon, GA

- Sue Binder, M.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- George L. Blackburn, M.D., Ph.D.
- New England Deaconess Hospital
- Boston, MA

- Steven Blair, P.E.D.
- Cooper Institute for Aerobics Research
- Dallas, TX

- David A. Blandino, M.D.
- Shadyside Hospital/AAFP
- Pittsburgh, PA

- C. Richard Boland, M.D.
- University of Michigan
- Ann Arbor, MI

- John H. Bond, M.D.
- University of Minnesota
- Minneapolis, MN

- Emily A. Boohaker, M.D.
- Georgetown University
- Washington, DC

- John W. Boslego, M.D.
- Walter Reed Army Institute of Research
- Washington, DC

- G. Stephen Bowen, M.D., M.P.H.
- Health Resources and Services Administration
- Rockville, MD

- John M. Bowman, M.D.
- Rh Laboratory
- Winnipeg, Manitoba

- William E. Boyle, Jr., M.D.
- Dartmouth Hitchcock Medical Center/AAP
- Lebanon, NH

- Katharine Bradley, M.D., M.P.H.
- Department of Veterans Affairs
- Seattle, WA

- William E. Brady, M.P.H.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Frederick L. Brancati, M.D., M.H.S.
- The Johns Hopkins University
- Baltimore, MD

- J. Timothy Bricker, M.D.
- Texas Children's Hospital
- Houston, TX

- Peter A. Briss, M.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- John W. Britt, R.N., M.P.H.
- Harborview Injury Prevention & Research Center
- Seattle, WA

- Robert Brodell, M.D.
- American Academy of Pediatrics
- Cumberland, MD

- Yvonne Bronner, Sc.D., R.D., L.D.
- The Johns Hopkins University
- Baltimore, MD

- Neil Brooks, M.D.
- Rockville Family Physicians, P.C./AAFP
- Rockville, CT

- W. Blair Brooks, M.D.
- Dartmouth Hitchcock Medical Center
- Lebanon, NH

- Zane A. Brown, M.D.
- University of Washington
- Seattle, WA

- Kendall J. Bryant, Ph.D.
- National Institutes of Health
- Rockville, MD

- Bill Bukoski, M.D.
- National Institutes of Health
- Bethesda, MD

- Lisa M. Bundara, M.P.H.
- National Institutes of Health
- Bethesda, MD

- William P. Bunnell, M.D.
- Loma Linda University
- Loma Linda, CA

- Virginia B. Burggraf, M.S.N., R.N.
- American Nurses Association
- Washington, DC

- Julie E. Buring, Sc.D.
- Brigham and Women's Hospital
- Boston, MA

- Mary Ann Burkman, M.P.H., R.D.
- Dairy Council of California
- San Ramon, CA

- Randall W. Burt, M.D.
- University of Utah
- Salt Lake City, UT

- Benjamin T. Burton, Ph.D.
- National Institutes of Health
- Bethesda, MD

- Jamie Calabrese, M.D.
- Mercy Hospital of Pittsburgh/AAP
- Pittsburgh, PA

- Mariel Caldwell, M.P.H., M.S., R.D.
- American Dietetic Association
- Chicago, IL

- C. Wayne Callaway, M.D.
- George Washington University
- Washington, DC

- John L. Cameron, M.D.
- The Johns Hopkins University
- Baltimore, MD

- Joseph Caprioli, M.D.
- American Academy of Ophthalmology
- San Francisco, CA

- C. Eugene Carlton, M.D.
- American Urological Association, Inc.
- Baltimore, MD

- David F. Carpenter, Ph.D.
- Illinois Department of Public Health
- Springfield, IL

- Joseph S. Carra
- U.S. Environmental Protection Agency
- Washington, DC

- H. Ballentine Carter, M.D.
- James Buchanan Brady Urological Institute
- Baltimore, MD

- Carl J. Caspersen, Ph.D., M.P.H.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Kenneth G. Castro, M.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Willard Cates, Jr., M.D., M.P.H.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Ralph R. Cavalieri, M.D.
- Department of Veterans Affairs Medical Center
- San Francisco, CA

- Arturo Cazares, M.D., M.P.H.
- National Institutes of Health
- Bethesda, MD

- David L. Chadwick, M.D.
- Children's Hospital Health Center/AAP
- San Diego, CA

- Evan Charney, M.D.
- University of Massachusetts
- Worcester, MA

- Vivian Chen, Sc.D., M.S.W.
- Health Resources and Services Administration
- Rockville, MD

- Robert T. Chen, M.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Ronni Chernoff, Ph.D., R.D.
- University of Arkansas
- Little Rock, AR

- Francis D. Chesley, M.D.
- Agency for Health Care Policy and Research
- Rockville, MD

- Emily Chew, M.D.
- National Institutes of Health
- Bethesda, MD

- James E. Childs, Sc.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- J. Julian Chisolm, Jr., M.D.
- The Johns Hopkins University
- Baltimore, MD

- Gerald W. Chodak, M.D.
- The University of Chicago
- Chicago, IL

- Terence L. Chorba, M.D., M.P.H.,M.P.A.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Katherine Kaufer Christoffel, M.D., M.P.H.
- The Children's Memorial Hospital
- Chicago, IL

- Carolyn Clancy, M.D.
- Agency for Health Care Policy and Research
- Rockville, MD

- Ellen W. Clayton, M.D.
- Vanderbilt University/AAP
- Nashville, TN

- James I. Cleeman, M.D.
- National Institutes of Health
- Bethesda, MD

- John D. Clemens, M.D.
- National Institutes of Health
- Bethesda, MD

- Janet C. Cleveland, M.S.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Nathaniel Cobb, M.D.
- Indian Health Service
- Albuquerque, NM

- Cecil H. Coggins, M.D.
- Massachusetts General Hospital
- Boston, MA

- Peter F. Cohn, M.D.
- State University of New York at Stony Brook
- Stony Brook, NY

- George C. Coleman, M.D.
- Medical College of Virginia/AAFP
- Richmond, VA

- George Cooney, Ph.D.
- Macquarie University
- Sydney, New South Wales, Australia

- James Cooper, M.D.
- Agency for Health Care Policy and Research
- Rockville, MD

- Judith A. Cooper, Ph.D.
- National Institutes of Health
- Rockville, MD

- Jose F. Cordero, M.D., M.P.H.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Lawrence Corey, M.D.
- University of Washington
- Seattle, WA

- E. Jane Costello, Ph.D.
- Duke University
- Durham, NC

- Edward O. Cox, M.D.
- American Academy of Pediatrics
- Grand Rapids, MI

- James Cox, M.D.
- Navajo Area Indian Health Service
- Gallup, NM

- Janet Cragan, M.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Thomas C. Croft
- Health Resources and Services Administration
- Rockville, MD

- Linda S. Crossett, R.D.H., B.S.
- Centers for Disease Control and Prevention
- Atlanta, GA

- George Cunningham, M.D., M.P.H.
- California State Department of Health
- Berkeley, CA

- Linda L. Dahlberg, M.A., Ph.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Peter R. Dallman, M.D. (ret.)
- University of California at San Francisco
- San Francisco, CA

- Thomas W. Davidson, M.D.
- Omaha Family Medicine/AAFP
- Omaha, NE

- Dana Davis, M.Ed.
- American School Health Association
- Kent, OH

- Michael P. Davis, M.A.
- National Institutes of Health
- Bethesda, MD

- Lauren DeAlleaume, M.D.
- St. Joseph's Medical Center/AAFP
- Yonkers, NY

- Felix F. de la Cruz, M.D.
- National Institutes of Health
- Bethesda, MD

- Margo A. Denke, M.D.
- University of Texas
- Dallas, TX

- Robert Dershewitz, M.D.
- Harvard Community Health Plan
- Braintree, MA

- Paul Dick, M.D.C.M., F.R.C.P.C.
- University of Toronto
- Toronto, Ontario

- Charlotte Dickinson, Ph.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Robert A. Dickson, M.A., Ch.M.
- University of Leeds
- Leeds, United Kingdom

- Allen Dietrich, M.D.
- Dartmouth Medical School
- Hanover, NH

- Kim N. Dietrich, Ph.D.
- University of Cincinnati
- Cincinnati, OH

- Susan E. Dietz, R.N., M.S.
- Centers for Disease Control and Prevention
- Atlanta, GA

- William Dietz, M.D., Ph.D.
- New England Medical Center
- Boston, MA

- Robin DiMatteo, Ph.D.
- University of California at Riverside
- Riverside, CA

- Jennifer L. Dingle, M.B.A.
- Dalhousie University
- Halifax, Nova Scotia

- Richard C. Dobyns, M.D., M.S.P.H.
- University of Iowa/AAFP
- Iowa City, IA

- Theodore C. Doege, M.D., M.S.
- American Medical Association
- Chicago, IL

- Karen Donato, M.S., R.D.
- National Institutes of Health
- Bethesda, MD

- Samuel W. Dooley, Jr., M.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Louise Doss-Martin, M.A., A.C.S.W.
- Health Resources and Services Administration
- Bethesda, MD

- Marion P. Downs, M.A., D.H.S.
- University of Colorado
- Denver, CO

- Joseph S. Drage, M.D.
- National Institutes of Health
- Bethesda, MD

- D. Peter Drotman, M.D., M.P.H.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Philippe Duclos, D.V.M., Ph.D.
- Laboratory Center for Disease Control
- Ottawa, Ontario

- Ann C. Duerr, Ph.D., M.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Johanna Dwyer, D.Sc., R.D.
- Frances Stern Nutrition Center
- Boston, MA

- Donald D. Dyson, M.D.
- Kaiser Permanente Medical Center
- Santa Clara, CA

- James R. Eckman, M.D.
- Emory University
- Atlanta, GA

- David M. Eddy, M.D., Ph.D.
- Kaiser Permanente Medical Care Program
- Pasadena, CA

- Kathryn M. Edwards, M.D.
- Vanderbilt University
- Nashville, TN

- Theodore C. Eickhoff, M.D.
- University of Colorado
- Denver, CO

- Tedd V. Ellerbrock, M.D., F.A.C.O.G.
- Centers for Disease Control and Prevention
- Atlanta, GA

- John B. Emans, M.D.
- Children's Orthopaedic Surgery Foundation
- Boston, MA

- Michael M. Engelgau, M.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Daniel R. Erickson, M.D.
- American Academy of Family Physicians
- Horicon, WI

- J. David Erickson, D.D.S., Ph.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Martin Erlichman, M.D.
- Agency for Health Care Policy and Research
- Rockville, MD

- Claire B. Ernhart, Ph.D.
- Case Western Reserve University
- Cleveland, OH

- Judith Ernst, D.M.Sc., R.D.
- Indiana University
- Indianapolis, IN

- E. Harvey Estes, Jr., M.D.
- North Carolina Medical Society Foundation, Inc.
- Raleigh, NC

- Bruce Ettinger, M.D.
- Kaiser Permanente Medical Care Program
- Oakland, CA

- Ruth A. Etzel, M.D.
- American Academy of Pediatrics
- Chamblee, GA

- Geoffrey Evans, M.D.
- Health Resources and Services Administration
- Rockville, MD

- Kenneth L. Evans, M.D.
- American Academy of Family Physicians
- Edmond, OK

- Bruce Lee Evatt, M.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- W. Douglas Everett, M.D., M.P.H.
- American Academy of Family Physicians
- Huntsville, AL

- Bernard G. Ewigman, M.D.
- University of Missouri at Columbia
- Columbia, MO

- Harmon J. Eyre, M.D.
- American Cancer Society
- Atlanta, GA

- Henry Falk, M.D., M.P.H.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Donna Falvo, Ph.D.
- Family Practice Center/AAFP
- Carbondale, IL

- David F. Fardon, M.D.
- Knoxville Orthopedic Clinic
- Knoxville, TN

- Denise J. Fedele, D.M.D., M.S.
- Department of Veterans Affairs
- Perry Point, MD

- John W. Feightner, M.D., M.Sc., F.C.F.P.
- McMaster University
- Hamilton, Ontario

- Bruce B. Feinberg, M.D.
- Brigham and Women's Hospital
- Boston, MA

- Bernadine Feldman, Ph.D.
- Agency for Health Care Policy and Research
- Rockville, MD

- William Feldman, M.D., F.R.C.P.C.
- Hospital for Sick Children
- Toronto, Ontario

- Jonathan E. Fielding, M.D., M.P.H.
- University of California at Los Angeles
- Santa Monica, CA

- Walter M. Fierson, M.D., P.C.
- American Academy of Pediatrics
- Elk Grove Village, IL

- David H. Filipi, M.D.
- HMO Nebraska/AAFP
- Omaha, NE

- Michael J. Fine, M.D., M.P.H.
- University of Pittsburgh
- Pittsburgh, PA

- Michael C. Fiore, M.D., M.P.H.
- University of Wisconsin at Madison
- Madison, WI

- Kenneth D. Fisher, Ph.D.
- Federation of American Societies for Experimental Biology
- Bethesda, MD

- Arthur C. Fleischer, M.D.
- Vanderbilt University
- Nashville, TN

- David Fleischer, M.D.
- American Society for Gastrointestinal Endoscopy
- Washington, DC

- Alan R. Fleischman, M.D.
- The New York Academy of Medicine/AAP
- New York, NY

- Michael F. Fleming, M.D., M.P.H.
- University of Wisconsin at Madison
- Madison, WI

- Food and Nutrition Board
- National Academy of Sciences
- Washington, DC

- Jacqueline Darroch Forrest, Ph.D.
- The Alan Guttmacher Institute
- New York, NY

- Willis R. Foster, M.D.
- National Institutes of Health
- Bethesda, MD

- Steven Fox, M.D., M.P.H.
- Agency for Health Care Policy and Research
- Rockville, MD

- John W. Frank, M.D., C.C.F.P., M.S., F.R.C.P.C.
- Ontario Workers' Compensation Institute
- Toronto, Ontario

- C. James Frankish, Ph.D.
- Institute of Health Promotion Research
- Vancouver, British Columbia

- Adele L. Franks, M.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Linda French, M.D.
- Oakwood Hospital/AAFP
- Dearborn, MI

- Gary D. Friedman, M.D.
- Kaiser Permanente Medical Care Program
- Oakland, CA

- Victor F. Froelicher, M.D.
- Stanford University
- Palo Alto, CA

- Paul G. Fuller, Jr., M.D.
- American Academy of Pediatrics
- Rome, NY

- Robinson Fulwood, M.S.P.H.
- National Institutes of Health
- Bethesda, MD

- Barbara Gaffield, M.S., R.D.
- Children's Hospital
- Oakland, CA

- Eduardo Gaitan, M.D., F.A.C.P.
- Department of Veterans Affairs Medical Center
- Jackson, MS

- Theodore G. Ganiats, M.D.
- University of California at San Diego/AAFP
- La Jolla, CA

- Alan Michael Garber, M.D., Ph.D.
- Department of Veterans Affairs
- Palo Alto, CA

- A. Isabel Garcia, D.D.S., M.P.H.
- Agency for Health Care Policy and Research
- Rockville, MD

- Pierce Gardner, M.D.
- State University of New York at Stony Brook
- Stony Brook, NY

- Robert J. Garrison, Ph.D.
- National Institutes of Health
- Bethesda, MD

- Marilyn H. Gaston, M.D.
- Health Resources and Services Administration
- Rockville, MD

- James R. Gavin, III, M.D., Ph.D.
- American Diabetes Association
- Alexandria, VA

- David W. Gelfand, M.D.
- Wake Forest University
- Winston-Salem, NC

- Melvin D. Gerald, M.D., M.P.H.
- Gerald Family Care Associates/AAFP
- Washington, DC

- A. Russell Gerber, M.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Marianne Gerson, M.D.
- Kaiser Permanente Medical Care Program
- Vallejo, CA

- Helen Gift, Ph.D.
- National Institutes of Health
- Bethesda, MD

- Wayne H. Giles, M.D., M.S.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Gary A. Giovino, Ph.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Fred S. Girton, M.D.
- Family Health Center/AAFP
- Macon, GA

- Cindy Quinton Gladstone, M.H.Sc.,M.D., F.R.C.P.C.
- University of Toronto
- Toronto, Ontario

- John Gohagan, Ph.D.
- National Institutes of Health
- Rockville, MD

- Dorothy Gohdes, M.D.
- Indian Health Service
- Albuquerque, NM

- Michael Goldberg, M.D.
- New England Medical Center/AAP
- Boston, MA

- Richard B. Goldbloom, O.C., M.D., F.R.C.P.C.
- Dalhousie University
- Halifax, Nova Scotia

- Robert L. Goldenberg, M.D.
- University of Alabama at Birmingham
- Birmingham, AL

- Lee Goldman, M.D.
- University of California at San Francisco
- San Francisco, CA

- Sherwin Goldman, M.D.
- Mayo Clinic
- Rochester, MN

- Ronald H. Goldschmidt, M.D.
- San Francisco General Hospital/AAFP
- San Francisco, CA

- Junius J. Gonzales, M.D.
- Georgetown University
- Washington, DC

- Nancy P. Gordon, Sc.D.
- Kaiser Permanente Medical Care Program
- Oakland, CA

- Barbara Gosink, M.D.
- University of California at San Diego
- San Diego, CA

- Madelyn S. Gould, Ph.D., M.P.H.2
- Columbia University
- New York, NY

- Laura B. Gowen
- National Scoliosis Foundation
- Watertown, MA

- Deborah Grady, M.D., M.P.H.
- University of California at San Francisco
- San Francisco, CA

- Philippe Grandjean, M.D., Ph.D.
- Odense Universitet
- Miljemedicin, Denmark

- Dan M. Granoff, M.D.
- American Academy of Pediatrics
- Berkeley, CA

- Gilman D. Grave, M.D.
- National Institutes of Health
- Bethesda, MD

- Joseph H. Graziano, Ph.D.
- Columbia University
- New York, NY

- Beverly B. Green, M.D., M.P.H.
- Group Health Cooperative of Puget Sound
- Bainbridge Island, WA

- Clarice A. Green, M.D., M.S.
- Centers for Disease Control and Prevention
- Atlanta, GA

- John L. Green, M.D.
- American Academy of Pediatrics
- Rochester, NY

- Lawrence W. Green, Dr.P.H.
- University of British Columbia
- Vancouver, British Columbia

- Lee Green, M.D., M.P.H.
- University of Michigan/AAFP
- Ann Arbor, MI

- John C. Greene, D.M.D., M.P.H. (ret.)
- University of California at San Francisco School of Dentistry
- San Rafael, CA

- Michael F. Greene, M.D.
- Brigham and Women's Hospital
- Boston, MA

- Donald E. Greydanus, M.D.
- Michigan State University/AAP
- Kalamazoo, MI

- Marie R. Griffin, M.D.
- Vanderbilt University
- Nashville, TN

- Don Gromisch, M.D.
- American Academy of Pediatrics
- Elk Grove Village, IL

- George A. Gross, D.O., M.P.H. (ret.)
- Michigan State University College of Osteopathic Medicine
- East Lansing, MI

- Peter A. Gross, M.D.
- Hackensack Medical Center
- Hackensack, NJ

- Robert D. Gross, M.D.
- Children's Eye Specialists/AAP
- Fort Worth, TX

- Ronald L. Gross, M.D.
- Baylor College of Medicine
- Houston, TX

- Erica P. Gunderson, M.S., M.P.H., R.D.
- American Dietetic Association
- Larkspur, CA

- Gordon Guyatt, M.D.
- McMaster University
- Hamilton, Ontario

- Julian Haber, M.D.
- American Academy of Pediatrics
- Fort Worth, TX

- James E. Haddow, M.D.
- Foundation for Blood Research
- Scarborough, ME

- Stephen C. Hadler, M.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Evan Hadley, M.D.
- National Institutes of Health
- Bethesda, MD

- Caroline Breese Hall, M.D.
- University of Rochester Medical Center/AAP
- Rochester, NY

- Neal Halsey, M.D.
- The Johns Hopkins University
- Baltimore, MD

- Edward N. Hanley, Jr., M.D.
- American Academy of Orthopaedic Surgeons
- Rosemont, IL

- W.B. Hanley, M.D.
- Hospital for Sick Children
- Toronto, Ontario

- W. Harry Hannon, Ph.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Toni J. Hanson, M.D.
- Mayo Clinic
- Rochester, MN

- Jeffrey Harris, M.D., M.P.H.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Birt Harvey, M.D.
- Packard Children's Hospital
- Palo Alto, CA

- Richard A. Hatch, O.D.
- Indian Health Service
- Gallup, NM

- Barton F. Haynes, M.D.
- Duke University
- Durham, NC

- R. Brian Haynes, M.D., Ph.D.,F.R.C.P.C.
- McMaster University
- Hamilton, Ontario

- Denise Haynie, Ph.D.
- National Institutes of Health
- Bethesda, MD

- Gregory W. Heath, D.Sc., M.P.H.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Susan C. Hellerstein, M.D., M.P.H.
- Beth Israel Hospital
- Boston, MA

- Charles G. Helmick, III, M.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Elina Hemminki, M.D., Ph.D.
- National Research and Development Centre for Welfare and Health
- Helsinki, Finland

- William R. Hendee, Ph.D.
- Medical College of Wisconsin
- Milwaukee, WI

- Eric Henley, M.D.
- Indian Health Service
- Albuquerque, NM

- Charles H. Hennekens, M.D., Dr.P.H.
- Brigham and Women's Hospital
- Boston, MA

- Carol Herbert, M.D.
- Institute of Health Promotion Research
- Vancouver, British Columbia

- James W. Herbert, M.D.
- American Academy of Pediatrics
- San Angelo, TX

- Moses Herrera, M.D.
- Medical Center Physicians, P.A./AAFP
- Nampa, ID

- Lisa J. Herrinton, Ph.D.
- Kaiser Permanente Medical Care Program
- Oakland, CA

- Jerome M. Hershman, M.D.
- American Thyroid Association
- Los Angeles, CA

- Stephen P. Heyse, M.D., M.P.H.
- National Institutes of Health
- Bethesda, MD

- Robert A. Hiatt, M.D., Ph.D.
- Kaiser Permanente Medical Care Program
- Oakland, CA

- Ronald J. Hicks, M.D.
- University of Oklahoma Health Sciences Center/AAFP
- Oklahoma City, OK

- Gerry B. Hill, M.D., Ch.B., M.Sc.
- Laboratory Centre for Disease Control
- Tunney's Pasture, Ottawa

- Washington C. Hill, M.D.
- Sarasota Memorial Hospital
- Sarasota, FL

- E. Susan Hodgson, M.D.
- Rutgers University/AAP
- Somerset, NJ

- C.C. Hoekstra, Ph.D.
- Child Audiological Center, University Hospital
- Nijmegen, Netherlands

- Joe Hollowell, M.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- King K. Holmes, M.D., Ph.D.
- University of Washington
- Seattle, WA

- David Holtgrave, Ph.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Neil A. Holtzman, M.D., M.P.H.
- The Johns Hopkins University
- Baltimore, MD

- Charles Homer, M.D.
- Children's Hospital/AAP
- Boston, MA

- teven Hotta, M.D., Ph.D.
- Agency for Health Care Policy and Research
- Rockville, MD

- Jan Howard, Ph.D.
- National Institutes of Health
- Rockville, MD

- Van Hubbard, M.D.
- National Institutes of Health
- Bethesda, MD

- William J. Hueston, M.D.
- Eau Claire Family Practice/AAFP
- Eau Claire, WI

- Stephen B. Hulley, M.D., M.P.H.
- University of California at San Francisco
- San Francisco, CA

- Corinne G. Husten, M.D., M.P.H.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Vince L. Hutchins, M.D.
- National Center for Education in MCH
- Arlington, VA

- Jay D. Iams, M.D.
- Ohio State University Hospital
- Columbus, OH

- Debbie M. Jackson, M.A.
- Health Resources and Services Administration
- Rockville, MD

- Laird G. Jackson, M.D.
- Thomas Jefferson University
- Philadelphia, PA

- Richard J. Jackson, M.D., M.P.H.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Ian Jacobs, M.D., M.R.C.O.G.
- Cambridge University Teaching Hospitals Trust
- Cambridge, England

- Richard F. Jacobs, M.D.
- Arkansas Children's Hospital/AAP
- Little Rock, AR

- A.D. Jacobson, M.D.
- American Academy of Pediatrics
- Phoenix, AZ

- Robert M. Jacobson, M.D.
- Mayo Clinic
- Rochester, MN

- Mary A. Jansen, Ph.D.
- Substance Abuse and Mental Health Administration
- Rockville, MD

- Carole Jenny, M.D.
- The Children's Hospital/AAP
- Denver, CO

- James Jerger, Ph.D.
- Journal of the American Academy of Audiology
- Houston, TX

- Patrick Johannes, P.H.A.
- Indian Health Service
- Albuquerque, NM

- Barry L. Johnson, Ph.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Denise Johnson, M.S.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Joy L. Johnson, Ph.D., R.N.
- University of British Columbia
- Vancouver, British Columbia

- Robert E. Johnson, M.D., M.P.H.
- Centers for Disease Control and Prevention
- Atlanta, GA

- A. Patrick Jonas, M.D.
- Ohio State University/AAFP
- Columbus, OH

- Donna S. Jones, M.D., M.P.H.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Wanda K. Jones, Dr.P.H.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Douglas E. Jorenby, Ph.D.
- University of Wisconsin at Madison
- Madison, WI

- Elaina R. Jurecki, M.S., R.D.
- Kaiser Permanente Medical Care Program
- Oakland, CA

- Norman M. Kaplan, M.D.
- University of Texas Southwestern Medical Center
- Dallas, TX

- William Kassler, M.D., M.P.H.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Wayne J. Katon, M.D.
- University of Washington
- Seattle, WA

- Samuel L. Katz, M.D.
- Duke University
- Durham, NC

- Steven C. Kaufman, M.D., M.S.
- National Institutes of Health
- Bethesda, MD

- Joseph W. Kelaghan, M.D.
- National Institutes of Health
- Bethesda, MD

- Arthur L. Kellermann, M.D., M.P.H.
- Emory Center for Injury Control
- Atlanta, GA

- Kathi J. Kemper, M.D., M.P.H.
- Harborview Medical Center/AAP
- Seattle, WA

- Karla Kerlikowske, M.D.
- University of California at San Francisco
- San Francisco, CA

- Muin J. Khoury, M.D., Ph.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Edwin M. Kilbourne, M.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Gail King, M.D., M.P.H.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Howard A. King, M.D.
- Children's Hospital and Medical Center
- Seattle, WA

- Douglas Kirby, Ph.D.
- ETR Associates
- Santa Cruz, CA

- Barbara Klein, M.D., M.P.H.
- University of Wisconsin at Madison
- Madison, WI

- Robert N. Kleinstein, O.D., M.P.H.,Ph.D.
- University of Alabama at Birmingham
- Birmingham, AL

- William J. Klish, M.D.
- Texas Children's Hospital/AAP
- Houston, TX

- Ruth N. Knollmueller, Ph.D., R.N.
- American Nurses Association
- Hamden, CT

- Richard Koch, M.D.
- Children's Hospital Los Angeles
- Los Angeles, CA

- Howard K. Koh, M.D., F.A.C.P.
- Boston University
- Boston, MA

- Steve Kohl, M.D.
- San Francisco General Hospital/AAP
- San Francisco, CA

- Ann M. Koontz, Dr.P.H.
- Health Resources and Services Administration
- Rockville, MD

- Daniel B. Kopans, M.D., F.A.C.R.
- Massachusetts General Hospital
- Boston, MA

- Lorrin M. Koran, M.D.
- Stanford University
- Stanford, CA

- Doreen Koretz, Ph.D.
- National Institutes of Health
- Bethesda, MD

- Thomas E. Kottke, M.D.
- Mayo Clinic
- Rochester, MN

- Barnett S. Kramer, M.D., M.P.H.
- National Institutes of Health
- Bethesda, MD

- Norman A. Krasnegor, Ph.D.
- National Institutes of Health
- Bethesda, MD

- Robert Kreisberg, M.D.
- University of Alabama at Birmingham
- Birmingham, AL

- David B. Krier, M.D., M.S.P.H.
- American Academy of Family Physicians
- St. Paul, OR

- Richard D. Krugman, M.D.
- University of Colorado/AAP
- Denver, CO

- Saul Krugman, M.D.
- New York University
- New York, NY

- Laura Kruse, M.D.
- Health Resources and Services Administration
- Rockville, MD

- Lewis H. Kuller, M.D., Dr.P.H.
- University of Pittsburgh
- Pittsburgh, PA

- Stephen La Franchi, M.D.
- Oregon Health Sciences University/AAP
- Portland, OR

- F. Marc LaForce, M.D.
- The Genesee Hospital
- Rochester, NY

- Kathleen A. Lamping, M.D.
- EENT Associates, Inc.
- South Euclid, OH

- Sandra A. Larsen, Ph.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Eric B. Larson, M.D., M.P.H.
- University of Washington
- Seattle, WA

- Reva C. Lawrence, M.P.H.
- National Institutes of Health
- Bethesda, MD

- Nancy C. Lee, M.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- R. Dee Legako, M.D.
- Canyon Park Family Physicians/AAFP
- Edmond, OK

- Rudolph L. Leibel, M.D.
- Rockefeller University
- New York, NY

- Richard A. Lemen, Ph.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Claude Lenfant, M.D.
- National Institutes of Health
- Bethesda, MD

- M. Cristina Leske, M.D., Ph.D.
- State University of New York at Stony Brook
- Stony Brook, NY

- Carl M. Leventhal, M.D.
- National Institutes of Health
- Bethesda, MD

- Gary I. Levine, M.D.
- Southwest Georgia Family Practice Residency/AAFP
- Albany, GA

- Harvey L. Levy, M.D.
- Children's Hospital
- Boston, MA

- Donald W. Lewis, D.D.S., D.D.P.H.,M.Sc.D., F.R.C.D.
- University of Toronto
- Toronto, Ontario

- Tracy Lieu, M.D., M.P.H.
- Kaiser Permanente Medical Care Program
- Oakland, CA

- Irwin Light, M.D.
- University of Cincinnati
- Cincinnati, OH

- Elmer S. Lightner, M.D.
- University of Arizona/AAP
- Phoenix, AZ

- Jane S. Lin-Fu, M.D.
- Health Resources and Services Administration
- Rockville, MD

- Robert Lindsay, M.B.Ch.B., Ph.D.
- Helen Hayes Hospital
- West Haverstraw, NY

- Mack Lipkin, Jr., M.D.
- New York University
- New York, NY

- Scott M. Lippman, M.D.
- University of Texas
- Houston, TX

- John R. Livengood, M.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- lexander G. Logan, M.D., F.R.C.P.C.
- Mount Sinai Hospital

- Toronto, Ontario
- Everett Logue, Ph.D.
- Family Practice Clinical Research Center/AAFP

- Akron, OH
- Jacob Lohr, M.D.
- University of North Carolina

- Chapel Hill, NC
- Douglas G. Long, M.D.
- American Academy of Family Physicians

- East Boothbay, ME
- John E. Lonstein, M.D.
- Minnesota Spine Center

- Minneapolis, MN
- Carolyn C. Lopez, M.D.
- Rush Prudential Health Plans/AAFP

- Chicago, IL
- Fred Lorey, Ph.D.
- California State Department of Health
- Berkeley, CA

- Betsy Lozoff, M.D., M.S.
- University of Michigan
- Ann Arbor, MI

- Russell V. Luepker, M.D.
- University of Minnesota
- Minneapolis, MN

- Sheila A. Lukehart, Ph.D.
- University of Washington
- Seattle, WA

- James Lustig, M.D.
- Denver General Hospital/AAP
- Denver, CO

- David A. Luthy, M.D.
- Swedish Medical Center
- Seattle, WA

- Jerry M. Lyle, M.D.
- Indian Health Service
- Rockville, MD

- Henry T. Lynch, M.D.
- Creighton University
- Omaha, NE

- Noni E. MacDonald, M.D., F.R.C.P.C.
- Children's Hospital of Eastern Ontario/AAP
- Ottawa, Ontario

- Michael I. MacEntee, Ph.D., L.D.S.(I),F.R.C.D.C.
- University of British Columbia
- Vancouver, British Columbia

- Abe Macher, M.D.
- Health Resources and Services Administration
- Rockville, MD

- Harriet L. MacMillan, M.D., F.R.C.P.C.
- Chedoke-McMaster Hospitals/McMaster University
- Hamilton, Ontario

- Kathryn R. Mahaffey, Ph.D.
- U.S. Environmental Protection Agency
- Cincinnati, OH

- Frank J. Mahoney, M.D
- Centers for Disease Control and Prevention
- Atlanta, GA

- Louis Emmet Mahoney, M.D., Dr.P.H.
- Health Resources and Services Administration
- Rockville, MD

- Lois A. Maiman, Ph.D.
- National Institutes of Health
- Bethesda, MD

- Jack S. Mandel, Ph.D., M.P.H.
- University of Minnesota
- Minneapolis, MN

- Marc Manley, M.D., M.P.H.
- National Institutes of Health
- Bethesda, MD

- R. Jerry Mann, M.D.
- University of Arkansas/AAFP
- Little Rock, AR

- Edgar K. Marcuse, M.D., M.P.H.
- Children's Hospital & Medical Center
- Seattle, WA

- Harold S. Margolis, M.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Donald W. Marianos, D.D.S., M.P.H.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Lauri Markowitz, M.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Morri Markowitz, M.D.
- Montefiore Medical Center
- Bronx, NY

- James S. Marks, M.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Susan Marks, R.N., M.S.N.
- Kaiser Permanente Medical Care Program
- Oakland, CA

- R.G. Mathias, M.D., F.R.C.P.C.
- University of British Columbia
- Vancouver, British Columbia

- Tim McAfee, M.D., M.P.H.
- Group Health Cooperative of Puget Sound
- Seattle, WA

- Elizabeth McAnarney, M.D.
- University of Rochester Medical Center/AAP
- Rochester, NY

- Jerome McAndrews, D.C.
- American Chiropractic Association
- Arlington, VA

- Patrick E. McBride, M.D., M.P.H.
- University of Wisconsin at Madison
- Madison, WI

- Harrison C. McCandless, M.D.
- American Academy of Family Physicians
- Torrance, CA

- Wayne McCormick, M.D.
- University of Washington
- Seattle, WA

- George McCoy, Ph.D.
- Indian Health Service
- Rockville, MD

- Judith McFarlane, Dr.P.H.
- Texas Woman's University
- Houston, TX

- Joan A. McGowan, Ph.D.
- National Institutes of Health
- Bethesda, MD

- Pamela McInnes, D.D.S., M.Sc.
- National Institutes of Health
- Bethesda, MD

- Pamela M. McMahon, Ph.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Lynn McQueen, M.S., M.P.H.
- Agency for Health Care Policy and Research
- Rockville, MD

- Robert Mecklenburg, D.D.S., M.P.H.
- National Institutes of Health
- Bethesda, MD

- Jack H. Medalie, M.D., M.P.H.
- Case Western Reserve University
- Cleveland, OH

- L.J. Melton, III, M.D.
- Mayo Clinic
- Rochester, MN

- James A. Mercy, Ph.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Gerald B. Merenstein, M.D.
- The Children's Hospital/AAP
- Denver, CO

- Gregory J. Mertz, M.D.
- University of New Mexico
- Albuquerque, NM

- Edward M. Messing, M.D., F.A.C.S.
- University of Wisconsin at Madison
- Madison, WI

- Curtis Mettlin, Ph.D.
- Roswell Park Cancer Institute
- Buffalo, NY

- Angela D. Mickalide, Ph.D.
- National SAFE KIDS Campaign
- Washington, DC

- Wm. Phillip Mickelson, M.D., M.A.
- Health Canada
- Ottawa, Ontario

- Anthony B. Miller, M.B., F.R.C.P.C.
- University of Toronto
- Toronto, Ontario

- Bess I. Miller, M.D., M.Sc.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Daniel S. Miller, M.D., M.P.H.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Stephen C. Miller, O.D.
- American Optometric Association
- St. Louis, MO

- Connie Mobley, Ph.D., R.D., L.D.
- University of Texas at San Antonio
- San Antonio, TX

- Alison A. Moore, M.D., M.P.H.
- University of California at Los Angeles
- Los Angeles, CA

- Barbara Moore, M.D.
- National Institutes of Health
- Bethesda, MD

- Prof. Michael R. Moore
- National Research Centre for Environmental Toxicology
- Brisbane, Queensland, Australia

- Dale C. Moquist, M.D.
- American Academy of Family Physicians
- Kansas City, MO

- John S. Moran, M.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Bruce Z. Morgenstern, M.D.
- Mayo Clinic
- Rochester, MN

- Gregory Morosco, Ph.D.
- National Institutes of Health
- Bethesda, MD

- John C. Morris, M.D.
- Mayo Clinic
- Rochester, MN

- Brenda J. Morrison, Ph.D.
- University of British Columbia
- Vancouver, British Columbia

- John C. Morrison, M.D.
- University of Mississippi Medical Center
- Jackson, MS

- Raymond T. Morrissy, M.D.
- Children's Orthopaedics of Atlanta
- Atlanta, GA

- James A. Mortimer, Ph.D.
- University of Minnesota
- Minneapolis, MN

- Eve K. Moscicki, Sc.D., M.P.H.
- National Institutes of Health
- Rockville, MD

- Susan M. Mou, M.D.
- University of Missouri
- Kansas City, MO

- Jean-Marie Moutquin, M.D.
- Hopital Saint-François d'Assise
- Quebec, Quebec

- Julie Graves Moy, M.D., M.P.H.
- Baylor College of Medicine/AAFP
- Houston, TX

- Joseph Mulinare, M.D., M.S.P.H.
- Centers for Disease Control and Prevention
- Atlanta, GA

- George E. Murphy, M.D.
- Washington University in St. Louis
- St. Louis, MO

- Alf L. Nachemson, M.D., Ph.D.
- Health Care Excellence
- Washington, DC

- Donald C. Nagel, M.D.
- American Academy of Family Physicians
- Black Mountain, NC

- National Association of School Nurses
- Scarborough, ME

- Marion Nestle, Ph.D., M.P.H.
- New York University
- New York, NY

- Susan Newcomer, Ph.D.
- National Institutes of Health
- Rockville, MD

- Thomas B. Newman, M.D., M.P.H.
- University of California at San Francisco
- San Francisco, CA

- Vicky Newman, M.S., R.D.
- Wellstart International/American Dietetic Association
- San Diego, CA

- Sheila A. Newton, Ph.D.
- National Institutes of Health
- Bethesda, MD

- Theresa A. Nicklas, Dr.P.H., L.D.N.
- Tulane University
- New Orleans, LA

- Lindsay E. Nicolle, M.D.
- University of Manitoba
- Winnipeg, Manitoba

- Richard Niska, M.D., F.A.C.E.P.
- Health Resources and Services Administration
- Rockville, MD

- Audrey H. Nora, M.D., M.P.H.
- Health Resources and Services Administration
- Rockville, MD

- J.W. Norris, M.D., F.R.C.P.C.
- University of Toronto
- North York, Ontario

- Charles North, M.D.
- Indian Health Service
- Albuquerque, NM

- Jerry L. Northern, Ph.D.
- University of Colorado
- Denver, CO

- Ruth Nowjack-Raymer, R.D.H., M.P.H.
- National Institutes of Health
- Bethesda, MD

- Lennarth Nysbrom, B.A.
- Umea University Hospital
- Umea, Sweden

- Denis M. O'Day, M.D., F.A.C.S.
- American Academy of Ophthalmology
- San Francisco, CA

- Godfrey P. Oakley, Jr., M.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Joseph Oesterling, M.D.
- University of Michigan
- Ann Arbor, MI

- James G. Olson, Ph.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Thomas C. Olsen, M.D.
- St. Joseph Mercy Community Health Care System/AAP
- Pontiac, MI

- Walter Orenstein, M.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Fred C. Osher, M.D.
- Agency for Health Care Policy and Research
- Rockville, MD

- Frank A. Oski, M.D.
- The Johns Hopkins University
- Baltimore, MD

- Gary L. Oxman, M.D., M.P.H.
- Multnomah County Health Department
- Portland, OR

- Pasquale J. Palumbo, M.D.
- Mayo Clinic
- Scottsdale, AZ

- Robert Pantell, M.D.
- University of California at San Francisco/ AAP
- San Francisco, CA

- Michael D. Parkinson, M.D., M.P.H.
- Health Resources and Services Administration
- Rockville, MD

- Patrick J. Parsons, Ph.D., C.Chem.,F.R.S.C.
- State of New York Department of Health
- Albany, NY

- Christopher Patterson, M.D., F.R.C.P.C.
- Chedoke-McMaster Hospitals
- Hamilton, Ontario

- Kay C. Pearson, R.Ph., M.P.H.
- Agency for Health Care Policy and Research
- Rockville, MD

- Jeffrey F. Peipert, M.D., M.P.H.
- Women and Infants'
- Providence, RI

- Thomas A. Peterman, M.D., M.Sc.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Kenneth Petersen, M.D.
- Indian Health Service
- Anchorage, AK

- Herbert B. Peterson, M.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- William R. Phillips, M.D., M.P.H.
- University of Washington/AAFP
- Seattle, WA

- Gregory A. Poland, M.D., F.A.C.P.
- Mayo Clinic
- Rochester, MN

- Ronald L. Poland, M.D., F.A.A.P.
- Pennsylvania State College of Medicine Children's Hospital
- Hershey, PA

- Malcolm H. Pope, M.D.
- University of Iowa
- Iowa City, IA

- Barry Portnoy, Ph.D.
- National Institutes of Health
- Bethesda, MD

- Barbara Millen Posner, Dr.P.H., R.D.
- Boston University
- Boston, MA

- Lloyd B. Potter, Ph.D., M.P.H.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Jerilynn Prior, M.D., F.R.C.P.C.
- University of British Columbia
- Vancouver, British Columbia

- Charles G. Prober, M.D.
- Stanford University
- Palo Alto, CA

- Bruce Psaty, M.D., Ph.D.
- University of Washington
- Seattle, WA

- Robert F. Purtell, Jr., M.D.
- American Academy of Family Physicians
- Milwaukee, WI

- Michelle A. Puryear, M.D., Ph.D.
- Health Resources and Services Administration
- Rockville, MD

- John T. Queenan, M.D.
- Georgetown University
- Washington, DC

- N. Regina Rabinovich, M.D., M.P.H.
- National Institutes of Health
- Bethesda, MD

- James A. Raczek, M.D.
- Eastern Maine Medical Center/AAFP
- Bangor, ME

- Juan Ramos, Ph.D.
- National Institutes of Health
- Bethesda, MD

- Peter Rappo, M.D.
- American Academy of Pediatrics
- West Bridgewater, MA

- Pamela A. Ratner, R.N.
- University of Alberta
- Vancouver, British Columbia

- Elizabeth Raymond, M.D., M.P.H.
- Family Health International
- Research Triangle Park, NC

- Barbara K. Redman, Ph.D., R.N.,F.A.A.N.
- The Johns Hopkins University
- Baltimore, MD

- Joan Reede, M.D., M.P.H.
- Harvard University/AAP
- Boston, MA

- Paul J. Reiss, M.D.
- Vermont Academy of Family Physicians/AAFP
- Willston, VT

- John T. Repke, M.D.
- Brigham and Women's Hospital
- Boston, MA

- Ken Resnicow, Ph.D.
- Emory University
- Atlanta, GA

- Sheldon M. Retchin, M.D., M.S.P.H.
- Medical College of Virginia
- Richmond, VA

- George G. Rhoads, M.D., M.P.H.
- The Environmental and Occupational Health Sciences Institute
- Piscataway, NJ

- Darrell S. Rigel, M.D.
- New York University
- New York, NY

- B. Lawrence Riggs, M.D.
- Mayo Clinic
- Rochester, MN

- Frederick P. Rivara, M.D., M.P.H.
- Harborview Medical Center
- Seattle, WA

- Milisa K Rizer, M.D., M.P.H.
- University of Texas at San Antonio/AAFP
- San Antonio, TX

- Helen Elizabeth Roberts, M.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Richard Roberts, M.D., J.D.
- University of Wisconsin at Madison/AAFP
- Madison, WI

- William O. Robertson, M.D.
- Washington Poison Center
- Seattle, WA

- Lee N. Robins, Ph.D.
- Washington University
- St. Louis, MO

- Edward J. Roccella, Ph.D.
- National Institutes of Health
- Bethesda, MD

- Roger B. Rodrigue, M.D., M.P.H.
- Medical Center of Delaware/AAFP
- Wilmington, DE

- Martha Rogers, M.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Michael Rosenberg, M.D., M.P.H.
- Health Decisions, Inc.
- Chapel Hill, NC

- Zeda F. Rosenberg, Sc.D.
- National Institutes of Health
- Bethesda, MD

- Lisa S. Rosenblum, M.D., M.P.H.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Edward C. Rosenow III, M.D., F.C.C.P.,F.A.C.P.
- Mayo Clinic
- Rochester, MN

- Anthony L. Rosner, Ph.D.
- Foundation for Chiropractic Education and Research
- Arlington, VA

- Douglas S. Ross, M.D.
- Massachusetts General Hospital
- Boston, MA

- Louise B. Russell, Ph.D.
- Rutgers University
- New Brunswick, NJ

- Marcia Russell, Ph.D.
- Research Institutes on Addictions
- Buffalo, NY

- Mark S. Ruttum, M.D.
- Medical College of Wisconsin
- Milwaukee, WI

- Benjamin P. Sachs, M.B., B.S.,
- D.P.H.(C)
- Beth Israel Hospital

- Boston, MA
- Henrietta Sachs, M.D. (ret.)
- Glencoe, IL

- Bertha H. Safford, M.D.
- American Academy of Family Physicians
- Ferndale, WA

- Marcel Salive, M.D., M.P.H.
- National Institutes of Health
- Bethesda, MD

- Daniel H. Saltzman, M.D.
- Brigham and Women's Hospital
- Boston, MA

- Linda E. Saltzman, Ph.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Neil H. Sampson, M.P.H., M.G.A.
- Health Resources and Services Administration
- Rockville, MD

- Jean E. Sanders, M.D.
- Fred Hutchinson Cancer Research Center/AAP
- Seattle, WA

- M. Olwen Sanderson, M.D.
- American Academy of Family Physicians
- Portland, OR

- Mathuram Santosham, M.D.
- The Johns Hopkins University
- Baltimore, MD

- Clark T. Sawin, M.D.
- Department of Veterans Affairs Medical Center
- Boston, MA

- Robert Sayers, M.D.
- American Academy of Pediatrics
- Ocean Springs, MS

- Charles A. Schable, M.S.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Lawrence Schachner, M.D.
- American Academy of Pediatrics
- Miami, FL

- Catherine Schaefer, Ph.D.
- Kaiser Permanente Medical Care Program
- Oakland, CA

- William Schaffner, M.D.
- Vanderbilt University
- ashville, TN

- James J. Schlesselman, Ph.D.
- University of Pittsburgh
- Pittsburgh, PA

- Candace M. Schlife, M.P.H.
- Indian Health Service
- Albuquerque, NM

- Edgar J. Schoen, M.D.
- Kaiser Permanente Medical Care Program
- Oakland, CA

- Herbert C. Schulberg, Ph.D.
- University of Pittsburgh
- Pittsburgh, PA

- Manuel Schydlower, M.D.
- William Beaumont Army Medical Center/AAP
- El Paso, TX

- Carol Jack Scott, M.D., M.S.Ed.,F.A.C.E.P.
- University of Maryland/The Medical Education Group, Inc.
- Baltimore, MD

- Gwendolyn B. Scott, M.D.
- University of Miami/AAP
- Miami, FL

- F. Douglas Scutchfield, M.D.
- San Diego State University
- San Diego, CA

- Margretta R. Seashore, M.D.
- Yale University/AAP
- New Haven, CT

- Joe Selby, M.D., M.P.H.
- Kaiser Permanente Medical Care Program
- Oakland, CA

- Mary C. Sengstock, Ph.D., C.C.S.
- Wayne State University
- Detroit, MI

- F.J. Service, M.D., Ph.D.
- Mayo Clinic
- Rochester, MN

- David Shaffer, M.D.
- Columbia University
- New York, NY

- Barbara Shannon, Ph.D.
- Pennsylvania State University
- University Park, PA

- Craig N. Shapiro, M.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Henry R. Shinefield, M.D.
- Kaiser Permanente Medical Care Program
- Oakland, CA

- Hugh M. Shingleton, M.D.
- American Cancer Society
- Atlanta, GA

- Barbara M. Shulman
- The Scoliosis Association, Inc.
- Raleigh, NC

- Baha M. Sibai, M.D.
- University of Tennessee at Memphis
- Memphis, TN

- Ellen K. Silbergeld, M.D.
- University of Maryland at Baltimore
- Baltimore, MD

- Denise G. Simons-Morton, M.D., Ph.D.
- National Institutes of Health
- Bethesda, MD

- Peter A. Singer, M.D.
- University of Southern California
- Los Angeles, CA

- David A. Sleet, Ph.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Jean Slutsky, P.A., M.S.P.H.
- Agency for Health Care Policy and Research
- Rockville, MD

- Clark B. Smith, M.D.
- University of Tennessee at Memphis/AAFP
- Memphis, TN

- Richard J. Smith, III
- Indian Health Service
- Rockville, MD

- Suzanne M. Smith, M.D., M.P.H.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Linda Snetselaar, Ph.D., R.D., L.D.
- University of Iowa
- Iowa City, IA

- David B. Snyder, R.P.H., D.D.S.
- Health Resources and Services Administration
- Rockville, MD

- Alfred Sommer, M.D., M.H.S.
- The Johns Hopkins University
- Baltimore, MD

- Edward J. Sondik, Ph.D.
- National Institutes of Health
- Bethesda, MD

- Stephen J. Spann, M.D.
- University of Texas at Galveston/AAFP
- Galveston, TX

- Marjorie A. Speers, Ph.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Carole A. Spencer, Ph.D., M.T.
- niversity of Southern California
- Los Angeles, CA

- Sachiko T. St. Jeor, Ph.D., R.D.
- University of Nevada
- Reno, NV

- Michael E. St. Louis, M.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Walter E. Stamm, M.D.
- University of Washington
- Seattle, WA

- Meir Stampfer, M.D., Dr.P.H.
- Harvard University
- Boston, MA

- Robert J. Stanley, M.D.
- American College of Radiology
- Reston, VA

- Jeffrey R. Starke, M.D.
- Texas Children's Hospital/AAP
- Houston, TX

- Pamela E. Starke-Reed, Ph.D., H.S.A., B.A.P.
- National Institutes of Health
- Bethesda, MD

- Jeffrey A. Stearns, M.D.
- University of Illinois at Rockford/AAFP
- Rockton, IL

- Russell W. Steele, M.D.
- Louisiana State University/AAP
- New Orleans, LA

- Bruce C. Steffens, M.D.
- American Academy of Family Physicians
- Moline, IL

- Martin T. Stein, M.D.
- University of California at San Diego/AAP
- La Jolla, CA

- Zena Stein, M.A., M.B., B.Ch.
- New York State Psychiatric Institute
- New York, NY

- William M. Steinberg, M.D.
- George Washington University
- Washington, DC

- Thomas Stephens, Ph.D.
- Thomas Stephens & Associates
- Manotick, Ontario

- Barbara Sternfeld, Ph.D.
- Kaiser Permanente Medical Care Program
- Oakland, CA

- Gene R. Sterritt, D.D.S., M.P.H.
- Centers for Disease Control and Prevention
- Atlanta, GA

- David Stoff, Ph.D.
- National Institutes of Health
- Rockville, MD

- Lisa B. Stollman, M.A., R.D.
- American Dietetic Association
- North Port, NY

- David Stone, Ph.D.
- Institute for Urban Health
- Boston, MA

- Katherine M. Stone, M.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Mary Story, Ph.D., R.D.
- University of Minnesota
- Minneapolis, MN

- D. Eugene Strandness, Jr., M.D.
- University of Washington
- Seattle, WA

- Victor Strasburger, M.D.
- American Academy of Pediatrics
- Elk Grove Village, IL

- Karen F. Strauss, M.S., R.D.
- Indian Health Service
- Rockville, MD

- Raymond A. Strikas, M.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Albert J. Stunkard, M.D.
- University of Pennsylvania
- Philadelphia, PA

- Roger F. Suchyta, M.D.
- American Academy of Pediatrics
- Elk Grove Village, IL

- Christina M. Surawicz, M.D., F.A.C.G.
- American College of Gastroenterology
- Arlington, VA

- Roland W. Sutter, M.D., M.P.H.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Judith Swan, M.H.S.
- National Institutes of Health
- Bethesda, MD

- Jack T. Swanson, M.D.
- McFarland Clinic/AAP
- Ames, IA

- Zachary Taylor, M.D., M.S.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Bruce D. Tempest, M.D., F.A.C.P.
- Indian Health Service
- Gallup, NM

- Milton Tenenbein, M.D.
- Children's Hospital/AAP
- Winnipeg, Manitoba

- Stephen B. Thacker, M.D., M.Sc.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Robert S. Thompson, M.D.
- Group Health Cooperative of Puget Sound
- Seattle, WA

- Robert H. Threlkel, M.D.
- American Academy of Pediatrics
- Jacksonville, FL

- James M. Tielsch, Ph.D.
- The Johns Hopkins University
- Baltimore, MD

- Donald D. Timmerman, M.D.
- Elmcrest Psychiatric Institute/AAFP
- Portland, CT

- Mary E. Tinetti, M.D.
- Yale University
- New Haven, CT

- Tokos Medical Corporation
- Cambridge, MA

- Riva Touger-Decker, Ph.D., R.D.
- University of Medicine and Dentistry of New Jersey
- Newark, NJ

- Frederick Trowbridge, M.D.
- Centers for Disease Control and Prevention
- Chamblee, GA

- Cyndee Trower, M.D.
- Health Resources and Services Administration
- Rockville, MD

- Myra Tucker, B.S.N., M.P.H.
- Centers for Disease Control and Prevention
- Atlanta, GA

- James R. Ullom
- Agency for Health Care Policy and Research
- Rockville, MD

- Ronald O. Valdiserri, M.D., M.P.H.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Peter C. Van Dyck, M.D., M.P.H.
- Health Resources and Services Administration
- Rockville, MD

- Theodore B. Van Itallie, M.D.
- St. Luke's-Roosevelt Hospital Center
- New York, NY

- Lester Van Middlesworth, Ph.D, M.D.
- University of Tennessee/Memphis
- Memphis, TN

- Gert J. Vanderwilt, Ph.D.
- Katholieke Universiteit Nijmegen
- Nijmegen, Netherlands

- Maria E. Vegega, Ph.D.
- National Highway Traffic Safety Administration
- Washington, DC

- M. Elsa Villarino, M.D., M.P.H.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Frank Vinicor, M.D., M.P.H.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Carey Vinson, M.D., M.P.M.
- Forbes Regional Hospital/AAFP
- Monroeville, PA

- Donna L. Vogel, Ph.D.
- National Institutes of Health
- Bethesda, MD

- H. Bruce Vogt, M.D.
- University of South Dakota
- Sioux Falls, SD

- William C. Wadland, M.D., M.S.
- Michigan State University/AAFP
- East Lansing, MI

- Bailus Walker, Jr., Ph.D., M.P.H.
- Alliance to End Childhood Lead Poisoning
- Washington, DC

- Elinor Walker
- Agency for Health Care Policy and Research
- Rockville, MD

- Michael D. Walker, M.D.
- National Institutes of Health
- Bethesda, MD

- Eric Wall, M.D., M.P.H.
- Oregon Health Sciences University/AAFP
- Portland, OR

- Mark E. Wallace, M.D., M.P.H.
- North Colorado Family Medicine/AAFP
- Greeley, CO

- Sharon L. Walmsley, M.D., F.R.C.P.C.
- University of Toronto
- Toronto, Ontario

- Patrick C. Walsh, M.D.
- The Johns Hopkins Hospital
- Baltimore, MD

- Elaine E.L. Wang, M.D. C.M., M.Sc.F.R.C.P.C.
- Hospital for Sick Children
- Toronto, Ontario

- Wendy Warren, M.D.
- American Academy of Family Physicians
- Klamath Falls, OR

- Reginald L. Washington, M.D.
- American Academy of Pediatrics
- Denver, CO

- Judith H. Wasserheit, M.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Thomas R. Waters, Ph.D.
- Centers for Disease Control and Prevention
- Cincinnati, OH

- Alan G. Waxman, M.D., M.P.H.
- Indian Health Service
- Gallup, NM

- Daniel W. Webster, Sc.D., M.P.H.
- The Johns Hopkins University
- Baltimore, MD

- Robert Weibel, M.D.
- Health Resources and Services Administration
- Rockville, MD

- Milton C. Weinstein, Ph.D.
- Harvard University
- Boston, MA

- Stuart L. Weinstein, M.D.
- University of Iowa
- Iowa City, IA

- Noel S. Weiss, M.D., Dr.P.H.
- University of Washington
- Seattle, WA

- Michael Weitzman, M.D.2
- Rochester General Hospital
- Rochester, NY

- Jay D. Wenger, M.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Martha M. Werler, Sc.D.
- Boston University
- Brookline, MA

- David J. West, Ph.D., M.P.H.
- Merck Research Laboratories
- West Point, PA

- David W. Wetter, Ph.D.
- University of Wisconsin at Madison
- Madison, WI

- Judith Whalen, M.P.A.
- National Institutes of Health
- Bethesda, MD

- Melinda E. Wharton, M.D., M.P.H.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Jane White, Ph.D., R.D.
- University of Tennessee at Knoxville
- Knoxville, TN

- John C. Whitener, O.D., M.P.H.
- American Optometric Association
- Alexandria, VA

- William L. Whittington, M.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- David O. Wiebers, M.D.
- Mayo Clinic
- Rochester, MN

- William H. Wiese, M.D., M.P.H.
- University of New Mexico
- Albuquerque, NM

- Lynne S. Wilcox, M.D., M.P.H.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Allan J. Wilke, M.D.
- Family Practice Center/AAFP
- St. Cloud, MN

- Stephen D. Williams, M.D.
- Indiana University Cancer Center
- Indianapolis, IN

- Walter W. Williams, M.D., M.P.H.
- Centers for Disease Control andPrevention
- Atlanta, GA

- David F. Williamson, Ph.D., M.S.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Sidney J. Winawer, M.D.
- Memorial Sloan-Kettering Cancer Center
- New York, NY

- Phyllis A. Wingo, Ph.D., M.S.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Peter D. Wood, D.Sc., Ph.D., F.A.C.S.M.
- Stanford University
- Palo Alto, CA

- Steffie Woolhandler, M.D.
- Harvard University
- Cambridge, MA

- Catherine E. Woteki, Ph.D., R.D.
- The White House, Office of Science Technology Policy
- Washington, DC

- David Wright, M.D.
- American Academy of Family Physicians
- Austin, TX

- Ray Yip, M.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Jonathan M. Zenilman, M.D.
- The Johns Hopkins University
- Baltimore, MD

- Gerhard Zielhuis, Ph.D.
- Katholieke Universiteit Nijmegen
- Nijmegen, Netherlands

- Richard Kent Zimmerman, M.D., M.P.H.
- University of Pittsburgh/AAFP
- Pittsburgh, PA

- Barry Zuckerman, M.D.
- Boston University
- Boston, MA