# Appendix A Task Force Ratings

The tables of ratings on the following pages were developed for the U.S. Preventive Services Task Force using the methodology adapted from the Canadian Task Force on the Periodic Health Examination [a] and described in Chapter ii. For this edition of the Guide, the Task Force developed ratings for all of the topics examined.

[a] Canadian Task Force on the Periodic Health Examination. The periodic health examination. Can Med Assoc J 1979121:1193-1254.

The Task Force graded the strength of recommendations for or against preventive interventions as follows.

[*] See relevant chapter for definition of high risk.

Strength of Recommendations

A: | There is good evidence to support the recommendation that the condition be specifically considered in a periodic health examination.
B: | There is fair evidence to support the recommendation that the condition be specifically considered in a periodic health examination.
C: | There is insufficient evidence to recommend for or against the inclusion of the condition in a periodic health examination, but recommendations may be made on other grounds.
D: | There is fair evidence to support the recommendation that the condition be excluded from consideration in a periodic health examination.
E: | There is good evidence to support the recommendation that the condition be excluded from consideration in a periodic health examination.

Determination of the quality of evidence (i.e., "good," "fair," "insufficient") in the strength of recommendations was based on a systematic consideration of three criteria: the burden of suffering from the target condition, the characteristics of the intervention, and the effectiveness of the intervention as demonstrated in published clinical research. Effectiveness of the intervention received special emphasis. In reviewing clinical studies, the Task Force used strict criteria for selecting admissible evidence and placed emphasis on the quality of study designs. In grading the quality of evidence, the Task Force gave greater weight to those study designs that, for methodologic reasons, are less subject to bias and inferential error. The following rating system was used.

Quality of Evidence

I: | Evidence obtained from at least one properly randomized controlled trial.
II-1: | Evidence obtained from well-designed controlled trials without randomization.
II-2: | Evidence obtained from well-designed cohort or case-control analytic studies, preferably from more than one center or research group.
II-3: | Evidence obtained from multiple time series with or without the intervention. Dramatic results in uncontrolled experiments (such as the results of the introduction of penicillin treatment in the 1940s) could also be regarded as this type of evidence.
III: | Opinions of respected authorities, based on clinical experience descriptive studies and case reports or reports of expert committees.

Well-designed and well-conducted meta-analyses were also considered, and were graded according to the quality of the studies on which the analyses were based (e.g., Grade I if the meta-analysis pooled properly randomized controlled trials).

An exact correlation does not exist between the strength of the recommendation and the level of evidence, i.e., Level I evidence did not necessarily lead to an "A" grade, nor did an "A" grade require Level I evidence. For example, there may have been evidence of good quality that did not prove that an intervention is effective (e.g., mammography in women under age 50, which received a "C" recommendation). On the other hand, an "A" recommendation was given to screening for cervical cancer with Papanicolaou testing, based on burden of suffering and Level II evidence supporting the effectiveness of the intervention. For many preventive services, there is insufficient evidence to determine whether or not routine intervention will improve clinical outcomes ("C" recommendation). A variety of different circumstances can result in a "C" recommendation: available studies are not adequate to determine effectiveness (e.g., insufficient statistical power, unrepresentative populations, lack of clinically important endpoints, or other important design flaws) high-quality studies have produced conflicting results evidence of significant benefits is offset by evidence of important harms from intervention or studies of effectiveness have not been conducted. As a result, lack of evidence of effectiveness does not constitute evidence of ineffectiveness. Chapter ii provides further information about the methodology used to develop the body of this report.

Table 1. Screening for Asymptomatic Coronary Artery Disease

Intervention | Level of Evidence | Strength of Recommendation
Routine resting, ambulatory, or exercise electrocardiography in middle-aged or older persons | II-2 | C
Routine resting electrocardiography in healthy children, adolescents, or young adults, including those undergoing pre participation sports physicals | III | D

Table 2. Screening for High Blood Cholesterol and Other Lipid Abnormalities

Intervention | Level of Evidence | Strength of Recommendation
Routine measurement of total serum or blood cholesterol
Men aged 35-65 yr | I, II-2 | B
Women aged 45-65 yr | II-2 | B
Persons aged > 65 yr | II-2 | C
Children, adolescents, young adults | II-2 | C
Routine measurement of HDL-C | II-2, III | C
Routine measurement of triglycerides | II-2 | C

Table 3. Screening for Hypertension

Intervention | Level of Evidence | Strength of Recommendation
Periodic blood pressure measurement in persons aged >= 21 yr | I | A
Measurement of blood pressure in children and adolescents during office visits | II-2, II-3, III | B

Table 4. Screening for Asymptomatic Carotid Artery Stenosis

Intervention | Level of Evidence | Strength of Recommendation
Routine carotid ultrasound or auscultation for carotid bruits in older persons | I, II-2 | C

Table 5. Screening for Peripheral Arterial Disease

Intervention | Level of Evidence | Strength of Recommendation
Routine history-taking for classic claudication, palpation of peripheral pulses, ultrasound, or other noninvasive tests in older persons | III | D

Table 6. Screening for Abdominal Aortic Aneurysm

Intervention | Level of Evidence | Strength of Recommendation
Routine abdominal palpation | II-2 | C
Routine abdominal ultrasound | II-2 | C

Table 7. Screening for Breast Cancer

Intervention | | | Level of Evidence | Strength of Recommendation
Routine mammogram every 1-2 yr with or without annual clinical breast exam
| Women aged | 40-49 yr | I | C
| | 50-69 yr | I, II-2 | A
| | 70-74 yr | I, II-3 | C
| | >= 75 yr | III | C
Annual clinical breast exam without periodic mammograms
| Women aged | 40-49 yr | III | C
| | 50-59 yr | I | C
| | >= 60 yr | III | C
Routine breast self-exam | | | I, II-2, III | C

Table 8. Screening for Colorectal Cancer

Intervention | Level of Evidence | Strength of Recommendation
Annual fecal occult blood testing of persons aged 50 yr and older | I, II-1, II-2 | B
Routine sigmoidoscopy in persons aged 50 yr and older | II-2, II-3 | B
Routine digital rectal exam | III | C
Routine barium enema | III | C
Routine colonoscopy | III | C

Table 9. Screening for Cervical Cancer

Intervention | Level of Evidence | Strength of Recommendation
Regular Pap testing in women who are or have been sexually active and who have a cervix | II-2, II-3 | A
Discontinuation of regular Pap testing in women aged >65 yr | III | C
Routine cervicography or colposcopy | III | C
Routine testing for HPV infection | III | C

Table 10. Screening for Prostate Cancer

Intervention | Level of Evidence | Strength of Recommendation
Routine digital rectal exam | II-2 | D
Routine prostate-specific antigen or other serum tumor markers | I, II-2, III | D
Routine transrectal ultrasound | II-2, III | D

Table 11. Screening for Lung Cancer

Intervention | Level of Evidence | Strength of Recommendation
Routine chest x-ray or sputum cytology | I, II-1, II-2 | D

Table 12. Screening for Skin Cancer---Including Counseling to Prevent Skin Cancer

Intervention | Level of Evidence | Strength of Recommendation
Screening
Total body skin exam by primary care clinicians | II-3, III | C
Periodic skin self-exam | II-3, III | C
Primary Prevention
Sun avoidance or use of protective clothing by high-risk[*] persons | II-2 | B
Routine use of sunscreens | I, II-2 | C
Clinician counseling to increase the use of sun protection measures | III | C

Table 13. Screening for Testicular Cancer

Intervention | Level of Evidence | Strength of Recommendation
Routine self-exam or physician exam of the testes in men | III | C

Table 14. Screening for Ovarian Cancer

Intervention | Level of Evidence | Strength of Recommendation
Routine pelvic exam, ultrasound, or serum tumor markers
General female population | II-3, III | D
High-risk[*] women | III | C

Table 15. Screening for Pancreatic Cancer

Intervention | Level of Evidence | Strength of Recommendation
Routine abdominal palpation, ultrasound, or serum tumor markers | III | D

Table 16. Screening for Oral Cancer

Intervention | Level of Evidence | Strength of Recommendation
Routine oral exam by primary care clinicians | III | C

Table 17. Screening for Bladder Cancer

Intervention | Level of Evidence | Strength of Recommendation
Routine urine dipstick or microscopy | II-2, III | D
Routine urine cytology | III | D

Table 18. Screening for Thyroid Cancer

Intervention | Level of Evidence | Strength of Recommendation
Routine neck palpation or ultrasound
General population | II-2, III | D
High-risk[*] adults or children | III | C

Table 19. Screening for Diabetes Mellitus

Intervention | Level of Evidence | Strength of Recommendation
Non-insulin-dependent
Routine measurement of plasma glucose, glycosylated hemoglobin, or urine glucose | II-2 | C
Gestational
Routine ora1-hr glucose challenge test, glycosolated hemoglobin, fasting or random plasma glucose, or urine glucose | I, II-2 | C
Insulin-dependent
Routine measurement of serum auto-antibodies in the general population | III | D

Table 20. Screening for Thyroid Disease

Intervention | Level of Evidence | Strength of Recommendation
Routine thyroid function tests
General population | III | D
High-risk[*] persons | I, II-3 | C

Table 21. Screening for Obesity

Intervention | Level of Evidence | Strength of Recommendation
Periodic height and weight measurements | I, II-2, II-3 | B
Routine determination of the waist/hip ratio | II-2 | C

Table 22. Screening for Iron Deficiency Anemia—Including Iron Prophylaxis

Intervention | | Level of Evidence | Strength of Recommendation
Screening
Routine hemoglobin/hematocrit
| Pregnant women at first prenatal visit | II-1, II-2 | B
| High-risk[*] infants | I | B
| High-risk[*] children | I | C
| General population | I, II-1, II-2 | C
Repeat hemoglobin/hematocrit in pregnant women or high-risk[*] infants not anemic at initial testing | | III | C
Primary Prevention
Breastfeeding and use of iron- enriched formula or food for all infants and toddlers | | I, II-1, II-2, II-3 | B
Routine use of iron supplements
| Healthy pregnant women | I, II-1, II-2 | C
| Healthy infants | I, III | C

Table 23. Screening for Elevated Lead Levels in Childhood and Pregnancy

Intervention | | Level of Evidence | Strength of Recommendation
Screening
Routine blood lead measurement
| High-risk[*] children | II-1, II-2, II-3 | B
| Pregnant women | III | C
Primary Prevention
Routinely counseling families to control lead dust by repeated household cleaning, or to optimize caloric, iron, and calcium intake specifically to reduce lead absorption | | II-2, III | C

Table 24. Screening for Hepatitis B Virus Infection

Intervention | Level of Evidence | Strength of Recommendation
Routine measurement of HBsAg
Pregnant women | I, II-1, II-2, II-3 | A
High-risk[*] persons (to assess eligibility for vaccination) | III | C
General population | III | D

Table 25. Screening for Tuberculous Infection—Including BCG Immunization

Intervention | Level of Evidence | Strength of Recommendation
Tuberculin skin testing of high-risk[*] persons | I | A
BCG vaccination of selected high-risk[*] infants and children | I, II-2 | B

Table 26. Screening for Syphilis

Intervention | Level of Evidence | Strength of Recommendation
Routine serologic testing
High-risk[*] persons | II-3 | A
Pregnant women | II-3 | A

Table 27. Screening for Gonorrhea—Including Ocular Prophylaxis in Newborns

Intervention | | Level of Evidence | Strength of Recommendation
Screening
Routine gonorrhea culture or nonculture screening test
| High-risk[*] women | II-2, III | B
| High-risk[*] pregnant women | II-2 | B
| Other pregnant women | III | C
| High-risk[*] men | II-3, III | C
| General population | III | D
Primary Prevention of Gonococcal Ophthalmia Neonatorum
Routine ophthalmic antibiotic in newborns | | II-3, III | A

Table 28. Screening for Human Immunodeficiency Virus Infection

Intervention | | Level of Evidence | Strength of Recommendation
Enzyme immunoassay, with confirmatory test for positive results
| High-risk[*] adolescents and adults | I, II-2 | A
| High-risk[*] pregnant women | I, II-2 | A
| High-risk[*] infants | II-2 | B
| Low-risk pregnant women, adolescents, and adults | III | C

Table 29. Screening for Chlamydial Infection—Including Ocular Prophylaxis in Newborns

Intervention | | Level of Evidence | Strength of Recommendation
Screening
Routine culture or nonculture screening test
| Sexually active female adolescents and other high-risk[*] women | I, II-2, III | B
| High-risk[*] pregnant women | II-2 | B
| Other pregnant women | III | C
| High-risk[*] men | II-3, III | C
| General population | III | D
Primary Prevention of Chlamydial Ophthalmia Neonatorum
Routine ophthalmic antibiotic in newborns | | I, II-2, III | C

Table 30. Screening for Genital Herpes Simplex

Intervention | | Level of Evidence | Strength of Recommendation
Screening
Routine viral culture, serology, or other tests
| General population | II-3, III | D
| Pregnant women | II-2, II-3, III | D
Examination of pregnant women in labor for signs of active genital HSV lesions | | II-2, III | C
Primary Prevention of Neonatal Herpes Infection
Routine use of systemic acyclovir in pregnant women with recurrent herpes | | III | C
Counseling uninfected women with infected partners to use condoms or abstain from intercourse during pregnancy | | III | C

Table 31. Screening for Asymptomatic Bacteriuria

Intervention | | Level of Evidence | Strength of Recommendation
Routine urine culture in pregnant women at 12-16 weeks' gestation | | I | A
Routine urine dipstick for leukocyte esterase/nitrites
| Pregnant women | II-2 | D
| Diabetic women | III | C
| Noninstitutionalized elderly women | I, II-1, II-2 | C
| Institutionalized elders | I | E
| School-aged girls | I | E
| Other persons | I, II-2, III | D
Routine urine microscopy | | II-2 | D

Table 32. Screening for Rubella—Including Immunization of Adolescents and Adults

Intervention | | Level of Evidence | Strength of Recommendation
Routine rubella serology or vaccination history
| Women of childbearing age (including pregnant women) | II-2, II-3, III | B
| Young men in high-risk[*] settings | II-3, III | C
| Other men and postmenopausal women | III | D
Routine rubella vaccination without screening
| Children | I, II-1, II-2, II-3 | A
| Nonpregnant women of childbearing age | II-2, III | B
| Young men in high-risk[*] settings | II-2, III | C
| Other men and postmenopausal women | III | D

Table 33. Screening for Visual Impairment

Intervention | Level of Evidence | Strength of Recommendation
Routine testing for amblyopia and strabismus in preschool children | II-1, II-2 | B
Routine Snellen acuity testing in elderly persons | II-3 | B
Routine ophthalmoscopy by primary care clinicians in elderly persons | III | C
Routine vision screening in other children, adolescents, and adults | III | C

Table 34. Screening for Glaucoma

Intervention | Level of Evidence | Strength of Recommendation
Routine tonometry | I, II-2, III | C
Routine ophthalmoscopy by primary care clinicians | III | C

Table 35. Screening for Hearing Impairment

Intervention | Level of Evidence | Strength of Recommendation
Periodically questioning older adults about their hearing | I, III | B
Routine audiometric testing in older adults | I, III | C
Routine hearing testing in adolescents and working-age adults [1] | III | C
Routine evoked otoacoustic emission testing or auditory brainstem response in newborns | II-2, III | C
Routine hearing testing in children aged >3 yr | II-2 | D

Table 36. Screening Ultrasonography in Pregnancy

Intervention | Level of Evidence | Strength of Recommendation
Routine midtrimester ultrasound in pregnant women | I | C
Routine third-trimester ultrasound in pregnant women | I | D

Table 37. Screening for Preeclampsia

Intervention | Level of Evidence | Strength of Recommendation
Periodic blood pressure measurement during pregnancy, as part of routine prenatal care | II-3, III | B

Table 38. Screening for D (Rh) Incompatibility

Intervention | | Level of Evidence | Strength of Recommendation
Routine D (Rh) blood typing and antibody testing of pregnant women at the first visit | | I, II-1, II-3 | A
Repeat antibody testing of all unsensitized D-negative pregnant women at 24-28 weeks' gestation | | II-1 | B
Routine administration of D immuno globulin to unsensitized D-negative women
| Postpartum | I, II-1 | A
| At 24-28 weeks' gestation | II-1 | B
| After amniocentesis or induced abortion | II-1, II-3 | B
| After CVS, other high-risk[*] obstetric procedures or complications | I, III | C

Table 39. Intrapartum Electronic Fetal Monitoring

Intervention | | Level of Evidence | Strength of Recommendation
Routine intrapartum electronic fetal monitoring
| Low-risk pregnancies | I | D
| High-risk[*] pregnancies | I | C

Table 40. Home Uterine Activity Monitoring

Intervention | | Level of Evidence | Strength of Recommendation
Home uterine activity monitoring
| Normal risk pregnancies | III | D
| High-risk[*] pregnancies | I, II-2 | C

Table 41. Screening for Down Syndrome

Intervention | Level of Evidence | Strength of Recommendation
Offering amniocentesis or CVS to high-risk[*] pregnant women | II-2 | B
Offering maternal serum multiple-marker testing to all pregnant women | II-2 | B
Offering maternal serum individual marker testing to pregnant women | II-2 | C
Offering midtrimester ultrasound to pregnant women | II-2, III | C

Table 42. Screening for Neural Tube Defects—Including Folate Prophylaxis

Intervention | Level of Evidence | Strength of Recommendation
Screening
Offering maternal serum alpha-fetoprotein measurement to all pregnant women | II-2 | B
Offering midtrimester ultrasound to all pregnant women | I, II-2, III | C
Primary Prevention
Periconceptional folic acid 4.0 mg daily for women with previous affected pregnancy | I | A
Daily multivitamin or multivitamin/multimineral containing 0.4-0.8 mg folic acid for women planning pregnancy | I, II-2 | A
Daily multivitamin containing 0.4 mg folic acid for women capable of pregnancy | II-2 | B
Dietary folate intake of 0.4 mg/day for women capable of pregnancy | II-2 | C

Table 43. Screening for Hemoglobinopathies

Intervention | | Level of Evidence | Strength of Recommendation
Testing for hemoglobinopathies in newborns | | I, II-2 | A
Offering testing for hemoglobinopathies with counseling
| Pregnant women at first prenatal visit | II-2, II-3, III | B
| High-risk[*] adolescents and young adults | II-1, III | C

Table 44. Screening for Phenylketonuria

Intervention | Level of Evidence | Strength of Recommendation
Routine measurement of phenylalanine level on dried-blood spot specimens in newborns | II-3 | A
Routine measurement of blood phenylalanine level in pregnant women | II-2, III | C

Table 45. Screening for Congenital Hypothyroidism

Intervention | Level of Evidence | Strength of Recommendation
Routine measurement of T_4_ and/or TSH on dried-blood spot specimens in newborns | II-3 | A

Table 46. Screening for Postmenopausal Osteoporosis

Intervention | Level of Evidence | Strength of Recommendation
Routine bone densitometry in postmenopausal women | II-2, III | C

Table 47. Screening for Adolescent Idiopathic Scoliosis

Intervention | Level of Evidence | Strength of Recommendation
Routine forward-bending test, visual inspection of the back, inclinometer, or other tests in adolescents | II-3, III | C

Table 48. Screening for Dementia

Intervention | Level of Evidence | Strength of Recommendation
Routine use of standardized screening tests in elderly persons | III | C

Table 49. Screening for Depression

Intervention | Level of Evidence | Strength of Recommendation
Routine use of standardized screening tests in primary care patients | I, II-1 | C

Table 50. Screening for Suicide Risk

Intervention | Level of Evidence | Strength of Recommendation
Screening
Routine use by primary care clinicians of direct questions or standardized screening tests in the general population | I, II-2, II-3 | C
Primary Prevention
Training primary care clinicians to recognize and treat affective disorders | II-3 | B

Table 51. Screening for Family Violence

Intervention | Level of Evidence | Strength of Recommendation
Routine standardized interview or physical exam to detect child abuse | III | C
Routine standardized interview to detect elder abuse | III | C
Routine standardized questionnaire to detect domestic violence | II-3, III | C

Table 52. Screening for Problem Drinking

Intervention | | Level of Evidence | Strength of Recommendation
Routine interview or standardized questionnaire to detect problem drinking
| Adolescents and adults | I, II-2 | B
| Pregnant women | II-2 | B

Table 53. Screening for Drug Abuse

Intervention | Level of Evidence | Strength of Recommendation
Routine screening with standardized questionnaires or biologic assays | III | C

Table 54. Counseling to Prevent Tobacco Use

Intervention | Level of Evidence | Strength of Recommendation
Efficacy of Risk Reduction
Avoidance or cessation of tobacco use to reduce the risk of cancer, cardiovascular and respiratory diseases, adverse pregnancy and neonatal outcomes, and effects of passive smoking | II-2 | A
Effectiveness of Counseling and Other Clinical Interventions
Clinician counseling of all patients, including pregnant women, who use tobacco to reduce or stop use | I | A
Nicotine patches or gum as an adjunct to counseling | I | A
Clonidine as an adjunct to counseling | I | C
Clinician counseling of school-aged children and adolescents to avoid tobacco use | III[1] | C

Table 55. Counseling to Promote Physical Activity

Intervention | Level of Evidence | Strength of Recommendation
Efficacy of Risk Reduction
Regular physical activity to prevent coronary heart disease, hypertension, obesity, and other diseases | II-2 | A
Effectiveness of Counseling
Counseling patients to incorporate regular physical activity into their daily routines | I, II-2 | C

Table 56. Counseling to Promote a Healthy Diet

Intervention | Level of Evidence | Strength of Recommendation
Efficacy of Risk Reduction in the General Population
Limiting intake of dietary fat (especially saturated fat) | I, II-2, II-3 | A
Limiting intake of dietary cholesterol | II-2 | B
Emphasizing fruits, vegetables and grain products containing fiber | II-2, II-3 | B
Maintaining caloric balance through diet and exercise | II-2 | B
Maintaining adequate intake of dietary calcium in women | I, II-1, II-2, II-3 | B
Reducing intake of dietary sodium | II-3 | C
Increasing intake of dietary iron | II-2, II-3, III | C
Increasing intake of beta-carotene and other antioxidants | II-2, II-3 | C
Breastfeeding infants | I, II-2 | A
Effectiveness of Counseling
Counseling to change dietary habits
- Specially trained educators | I[1] | B
- Primary care clinicians | III | C

Table 57. Counseling to Prevent Motor Vehicle Injuries

Intervention | Level of Evidence | Strength of Recommendation
Efficacy of Risk Reduction
Child safety seats, lap/shoulder belts, and motorcycle helmets | II-2, II-3 | A
Avoidance of driving while impaired by alcohol or other drugs | II-2, II-3 | A
Driver- and passenger-side air bags | II-2 | A
Alteration of pedestrian behavior | II-1, II-2, II-3 | C
Effectiveness of Counseling
Counseling parents to have their children use car safety seats or seat belts as appropriate for age | I, II-1, II-2 | B
Counseling adolescent and adult patients to use lap/shoulder belts | II-1, II-3 | B
Counseling patients to use motorcycle helmets | III | C
Counseling problem drinkers to reduce their alcohol consumption (see Ch. 52) | I | B
Counseling patients to avoid driving while impaired by alcohol or other drugs | III | C
Counseling patients and parents of child patients on safe pedestrian behavior | III | C

Table 58. Counseling to Prevent Household and Recreational Injuries

Intervention | Level of Evidence | Strength of Recommendation
Efficacy of Risk Reduction
Fires and Burns
Properly installed/tested smoke detectors | II-2 | B
Smoking cessation (see Ch. 54) | II-2 | A
Flame-retardant sleepwear for children | II-3 | A
Hot water heaters set to <120-130 degrees F | II-3 | A
Drowning
Four-foot, four-sided isolation fences with self-latching gates | II-2 | B
Cardiopulmonary resuscitation (CPR) training | II-2, III | B
Poisonings
Child-proof containers for medications | II-3 | A
Limitation of number of tablets packaged | II-3 | A
Poison-warning stickers designed for children (e.g., "Mr. Yuk" stickers) | II-1 | D
Bicycling and ATV Injuries
Approved bicycle and ATV helmets | II-2, II-3 | A
Avoidance of bicycling near traffic | II-2, III | B
ATVs with smaller engines and 4 wheels | II-2 | B
Training in safe bicycling behavior | I, III | C
Alcohol-Related Injuries
Avoidance of swimming, boating, bicycling, hunting, or smoking while intoxicated | II-2 | B
Falls in Children
Window guards in high-risk[*] buildings | II-3 | A
Falls in Elderly Persons
Exercise, especially balance training | I, II-1, II-2 | B
Home-based multifactorial fall prevention interventions in high-risk[*] elders | I, II-2 | B
External hip protectors in institutionalized elderly persons | II-1 | C
Other Injury Prevention Measures
(see Ch. 58 for details) | III | C
Effectiveness of Counseling
Counseling parents of young children on measures to reduce injury risk | I, II-1, II-2, II-3 | B
Counseling adolescents and adults on measures to reduce injury risk | I, III | C
Counseling problem drinkers to reduce alcohol consumption (see Ch. 52) | I | B
Counseling elderly patients to address risk factors for falls | I | C

Table 59. Counseling to Prevent Youth Violence

Intervention | Level of Evidence | Strength of Recommendation
Efficacy of Risk Reduction
Removal or safe storage of firearms in the home | II-2, II-3, III | B
Acquisition of interpersonal - problem solving skills | II-2, III | C
Reduction of heavy or problem drinking | II-2, II-3, III | B
Reduction of illicit drug use or drug trafficking | II-2, III | C
Effectiveness of Counseling
Counseling problem drinkers to reduce alcohol consumption (see Ch. 52) | I | B
Counseling on measures to reduce violence risk | III | C

Table 60. Counseling to Prevent Low Back Pain

Intervention | Level of Evidence | Strength of Recommendation
Efficacy of Risk Reduction
Exercise to strengthen back or abdominal muscles or to improve overall fitness | I, II-1, II-2 | C
Corsets/back belts | I, II-2 | C
Modification of risk factors (smoking, obesity, psychological factors) | II-2, III | C
Effectiveness of Counseling
Back pain prevention education
- Workplace | I, II-1, II-2 | C
- Pregnant women | II-1 | C
- Primary care patients | III | C

Table 61. Counseling to Prevent Dental and Periodontal Disease

Intervention | Level of Evidence | Strength of Recommendation
Efficacy of Risk Reduction
Regular visits to dental care provider (for services such as professionally applied topical fluorides, sealants) | I | B
Toothbrushing with fluoride-containing toothpaste | I, III | B
Dental flossing | II-1 | B
Avoidance of putting infants and children to bed with a bottle | II-2, III | B
Reduced and less frequent intake of sugary foods | II-2 | C
Fluoride supplementation of persons aged <=16 yr, in areas with inadequate water fluoridation | II-1 | A
Effectiveness of Counseling
Counseling patients (parents) to follow measures to reduce their (their children's) risk of oral disease | II-2, II-3 | C

Table 62. Counseling to Prevent HIV Infection and Other Sexually Transmitted Diseases

Intervention | Level of Evidence | Strength of Recommendation
Efficacy of Risk Reduction
Sexual abstinence or maintenance of mutually faithful monogamous sexual relationship | II-2 | A
Regular use of condoms | II-2, II-3 | A
Regular use of female barrier contraceptives and spermicides | I ^[1]^ , II-2 | B
Effectiveness of Counseling
Avoidance of contaminated injection equipment | II-2 | A
Counseling by primary care clinicians to reduce high-risk[*] sexual behavior or injection drug use | I, II-2 | C

Table 63. Counseling to Prevent Unintended Pregnancy

Intervention | Level of Evidence | Strength of Recommendation
Efficacy of Risk Reduction
Sexual abstinence or regular use of contraceptives | II-2 | A
Effectiveness of Counseling
Clinician counseling to improve use of contraceptives | II-3 | B
Clinician counseling to promote sexual abstinence among adolescents | III | C

Table 64. Counseling to Prevent Gynecologic Cancers

Intervention | Level of Evidence | Strength of Recommendation
Efficacy of Risk Reduction
Oral contraceptives to prevent ovarian and endometrial cancer | II-2 | B
Avoidance of high-risk[*] sexual activity, use of barrier contra- ceptives and spermicides to prevent cervical cancer | II-2 | A
Tubal sterilization to prevent ovarian cancer | II-2 | B
Effectiveness of Counseling
Counseling about measures to reduce risk of gynecologic cancers | III | C

Table 65. Childhood Immunizations[1]

Intervention | Level of Evidence | Strength of Recommendation
Routine Childhood Immunizations
Diphtheria Pertussis Tetanus Poliomyelitis Measles Rubella Mumps | I, II-3 | A
H. influenzae type b conjugate | I, II-1, II-2, II-3 | A
Hepatitis B | I, II-2, II-3 | A
Varicella | I, II-3 | A
Immunizations for High-Risk [*] Children
Hepatitis A (age >=2 yr) | I, II-3 | A
Influenza (age >=6 mo) (see Ch. 66) | II-2 | B
Pneumococcus (age >=2 yr) (see Ch. 66)
- Immunocompetent | I, II-2 | B
- Immunocompromised | I, II-2 | C
- Healthy persons living in epidemic conditions | I | A
Chemoprophylaxis Against Influenza A
Amantadine/rimantadine - for high risk[*] children (see Ch. 66) | I | B

[1] See Ch. 25 for recommendations on the use of BCG vaccine against tuberculosis.

Table 66. Adult Immunizations—Including Chemoprophylaxis Against Influenza A

Intervention | Level of Evidence | Strength of Recommendation
Routine Adult Immunizations
Influenza (age >=65 yr) | I, II-2 | B
Pneumococcus (age >=65 yr) | II-2 | B
Tetanus-diphtheria | I, II-3 | A
Hepatitis B (young adults) | I, II-3 | A
Immunizations for High-Risk [*] Adults
Influenza | II-2 | B
Pneumococcus
- Immunocompetent | I, II-2 | B
- Immunocompromised | I, II-2 | C
- Healthy young adults living in epidemic conditions | I | A
Hepatitis B | I, II-3 | A
Hepatitis A | I | B
Measles-mumps-rubella | I | A
Measles-mumps-rubella (second dose) | II-2, II-3 | B
Varicella (see Ch. 65) | I, II-3 | B
Chemoprophylaxis Against Influenza A
Amantadine/rimantadine for high-risk[*] adults | I | B

Table 67. Postexposure Prophylaxis for Selected Infectious Diseases

Disease | Intervention | Level of Evidence | Strength of Recommendation
H. influenzae type b | Rifampin | I, II-3 | A
Hepatitis A | Immune globulin | II-1 | A
Hepatitis B | Immune globulin/vaccine | I | A
N. meningitidis | Rifampin | I, II-1 | A
N. meningitidis | Vaccine ^[1]^ | I, II-1, II-3 | A
N. meningitidis | Ceftriaxone | I | C ^[2]^
Rabies | Immune globulin/ postexposure vaccine | I, II-3 | A
Rabies | Preexposure vaccine in high-risk[*] persons | II-1 | A
Tetanus | Vaccine/immune globulin | II-1, II-2, II-3 | A

Table 68. Postmenopausal Hormone Prophylaxis

Intervention | Level of Evidence | Strength of Recommendation
Routinely counseling peri- and postmenopausal women about the risks and benefits[1] of hormone prophylaxis | I, II-2 | B

Table 69. Aspirin Prophylaxis for the Primary Prevention of Myocardial Infarction

Intervention | Level of Evidence | Strength of Recommendation
Routine aspirin prophylaxis
- Middle-aged or older men | I | C
- Middle-aged women | II-2 | C

Table 70. Aspirin Prophylaxis in Pregnancy

Intervention | Level of Evidence | Strength of Recommendation
Routine aspirin prophylaxis to prevent preeclampsia
- Pregnant women | I | C
- High-risk[*] pregnant women | I | C
Routine aspirin prophylaxis to prevent intrauterine growth retardation in high-risk[*] pregnant women | I, II-1 | C