# IMMUNIZATIONS AND CHEMOPROPHYLAXIS

65 Childhood Immunizations

66 Adult Immunizations— Including Chemoprophylaxis Against Influenza A

67 Postexposure Prophylaxis for Selected Infectious Diseases

68 Postmenopausal Hormone Prophylaxis

69 Aspirin Prophylaxis for the Primary Prevention of Myocardial Infarction

70 Aspirin Prophylaxis in Pregnancy