# Counseling to Prevent Dental and Periodontal Disease

## Burden of Suffering

A large proportion of the population of the U.S. suffers from dental caries (tooth decay) and periodontal (gum and bone) disease. Although the prevalence of dental caries among school-aged children has declined in recent years, the most recent national survey (1986-1987) indicates that the average schoolchild has at least one cavity in permanent teeth by age 9, three cavities by age 12, and eight cavities by age 17.^ 1 ^ About one quarter have five or more decayed, missing, or filled teeth.^ 1 ^ In 1986-1987, about 50% of children age 5-17 were completely free of decay and of restorations in their permanent teeth.^ 1 ^ The average adult in the U.S. has 10-17 decayed, missing, or filled permanent teeth.^ 2 ^

About half of all adults have gingivitis (gum inflammation), and 80% have experienced some degree of periodontitis (inflammation of the gums leading to destruction of the bone supporting the teeth).^3,4^ About 60% of children and adolescents have at least one tooth site with gingival bleeding.^ 5 ^ Ninety-five percent of elderly persons have periodontitis, with more than one third experiencing moderate to severe periodontal disease (i.e., at least one site with attachment loss of 6 mm or greater).^ 2 ^ About 22% of American adults over age 45, and over half of adults over age 65, are edentulous.^ 6 ^ In 1989, dental conditions accounted for 164 million hours of missed work, 51 million hours of missed school, and 41 million restricted activity days in the U.S.^ 7 ^ Dental expenditures in the U.S. exceeded $30 billion in 1990.^ 8 ^ Dental and periodontal diseases are more common in persons whose personal behaviors (e.g., tobacco use, alcohol abuse, poor diet), medications, or coexisting medical illnesses (e.g., diabetes mellitus, xerostomia, Sjögren syndrome, human immunodeficiency virus [HIV] infection) increase the risk of oral pathology. Dental caries is also more common among minorities and children whose parents are of low socioeconomic status.^ 9 ^

Tooth and gum diseases are part of an overall category of oral health that includes conditions that fall outside the dental focus of this review (e.g., orofacial pain, salivary conditions, congenital anomalies). These include oral conditions that are manifestations of systemic diseases or treatment modalities. With the aging of the population, a growing number of older Americans are experiencing chronic diseases and taking medications that affect their oral health. The exclusion of these conditions from this discussion is not meant to minimize their important effect on other health behaviors (e.g., nutrition) and overall well-being, their importance as a source of morbidity or mortality in the U.S., the role of certain health behaviors (e.g., tobacco use) in causing these conditions, or the potential benefits of early detection by clinicians.^ 10 ^

## Efficacy of Risk Reduction

Personal oral disease prevention practices can reduce the risk of developing caries and periodontal disease. These measures include regular use of fluoride and some antiplaque and antigingivitis chemical agents, reduced amount and frequency of dietary intake of foods containing refined sugars or adherent carbohydrates, and tooth brushing and flossing. The incidence of caries has been reduced significantly by the fluoridation of community water supplies.^11-16^ Although 87% of the U.S. population is served by community water supplies, only 62% of these communities have optimally fluoridated water.^ 17 ^ In locations where adequate community water fluoridation is not available, the risk of caries can be reduced by providing alternate sources of fluoride.^18-23^ These sources include systemic (e.g., school water fluoridation, and fluoride tablets and drops) and topical (e.g., fluoride mouth rinse, professional fluoride treatment) forms. Virtually all toothpastes sold in the U.S. contain fluoride, which has been shown to be effective in reducing the incidence of caries by about 20-40%.^24,25^

The adverse effects of water fluoridation appear to be minimal. Although an increase in the prevalence of dental fluorosis has been observed,^26,27^ this trend has been attributed to inappropriate use of fluoride supplements by health professionals and parents.^28,29^ Inappropriate use of fluoride supplements and fluoride dentifrices is particularly common among infants and toddlers, who may swallow large amounts of fluoridated toothpaste.^30,31^ Most cases are mild and do not affect the appearance of teeth. Observational studies have provided conflicting evidence regarding the association between fluoride ingestion and the incidence of osteoporosis and hip fractures.^32-37^

Nonfluoride chemicals contained in some mouthwashes and gels may also be effective as antiplaque and antigingivitis agents.^38-40^ Regular use of some phenolic antiseptic mouthwashes (e.g., Listerine) has been associated with a 28-34% reduction in plaque and gingivitis at 6-month followup.^41-43^ Chlorhexidine gluconate rinses, when combined with toothbrushing, have been reported to achieve 50-55% reduction in plaque and a 45% reduction in gingivitis^44-46^ but the product can also stain teeth, increase calculus deposition, and produce an unpleasant taste. Dentifrices containing triclosan, when combined with zinc citrate or a copolymer of methoxyethylene and maleic acid, have been associated with a significant reduction in plaque and gingivitis,^47-50^ but the products are currently not available in the U.S.

Reduced exposure of the teeth to certain dietary carbohydrates, especially refined sugars and carbohydrates that adhere to the teeth, may lower the risk of developing caries. Studies in the 1950s and 1960s conducted in institutionalized settings suggested that diets including large amounts or frequent consumption of sucrose and other sugary foods were associated with a higher incidence of caries.^51,52^ The correlation has been more difficult to demonstrate in more recent studies, in which dietary intake was less carefully controlled, but the data are suggestive that the consumption of sugary foods, especially between meals, is cariogenic.^53-58^ Some data from animal studies also support this conclusion. For ethical reasons, definitive studies to prove a causal relationship between diet and carious lesions in humans are unlikely to be performed.

Improper infant feeding practices are another postulated source of caries in young children, especially the cariogenic damage to the maxillary incisors seen in early childhood caries (baby bottle tooth decay). This condition was first attributed to prolonged pooling of liquids around the anterior primary teeth in infants who regularly fall asleep sucking the nipple of a baby bottle containing an acidic or cariogenic beverage (fruit juice, soda, and formula).^ 59 ^ The etiology of the condition now appears to be multifactorial, and an association between infant feeding practices and early childhood caries is less clear.^60-62^ Some evidence suggests that other dietary factors and vertical transmission of certain bacteria from the mother may play an etiologic role.^ 62a ^ Education to curb the practice of putting children to bed with a bottle, encouragement of breastfeeding, early restoration and treatment of tooth decay, and optimizing the oral health care of the mother have each been proposed to decrease the risk of early childhood caries, but definitive evidence of effectiveness is lacking.

It is mainly the fluoride contained in toothpastes, rather than toothbrushing and flossing per se, that reduces tooth decay. It has been known for two decades, however, that brushing and flossing can prevent the development and progression of periodontal disease by removing bacterial plaque deposits.^63-65^ Mechanical interdental cleaning (e.g., flossing) and toothbrushing appear to be more effective than toothbrushing alone or antimicrobial mouth rinses in reducing gingivitis.^66,67^ Their efficacy, however, depends on the ability of the patient to keep teeth adequately plaque-free, and this necessitates thorough daily tooth brushing and cleaning between teeth with dental floss or other mechanical devices. It is unclear whether home electrical toothbrushes with rotating bristles are more effective than manual brushing in removing plaque and controlling gingivitis.^68-70^ These devices may be of greater benefit for persons with physical limitations due to arthritis or other conditions. Due to the difficulty many patients have in adopting and maintaining these habits, personal oral hygiene measures often fail to remove plaque adequately and prevent gingivitis. For this reason, it is also important for patients to receive regular professional dental care.

Different types of professional care are provided by dental specialists, dental hygienists, and dental public health professionals. Among the most important measures performed by dentists and dental hygienists are primary preventive measures, such as prophylactic scaling and root planing of teeth, and secondary preventive maneuvers, such as careful oral and dental examination for the early detection and treatment of dental disease. Other potentially effective preventive interventions offered by dental health professionals include the application of topical fluoride^71,72^ and occlusal sealants^73-75^ to prevent caries, placement of orthodontic space-maintaining appliances to prevent malocclusion, and the early detection of oral cancer (see Chapter 16) and the oral manifestations of infection with HIV (see also Chapter 28). Experimental studies in the 1970s demonstrated that meticulous and very frequent dental prophylaxis can reduce the incidence of caries in schoolchildren,^76-81^ but these studies required an intense program of professional dental care that would not be feasible under typical dental practice conditions in the U.S. Other studies suggest that topical fluoride application may be equally effective with or without dental prophylaxis, making it unclear whether the procedure needs to be restricted to dental practices.^ 39 ^ Professional care can also delay progression of periodontal disease because the dentist or dental hygienist can remove plaque and calculus from subgingival areas generally not reached by the patient. Professional dental care alone, however, is inadequate to prevent periodontal disease. Failure by the patient to regularly remove plaque deposits between dental visits can lead to extension of supragingival plaque beneath the gum, bacterial recolonization of the gingival crevice, accumulation of calculus, and recurrent periodontitis.^ 83 ^ Thus, regimens that combine personal oral hygiene with professional prophylaxis are most effective in the prevention of periodontal disease.^ 84 ^

Although annual (or more frequent) dental examinations and prophylaxis are often recommended, there is little scientific evidence that this frequency is necessary on a routine basis for the maintenance of oral health in asymptomatic persons. Regular examinations may be necessary to detect and treat disease processes before they threaten the viability of the teeth, gums, and other oral soft tissues in addition, more frequent visits may be necessary for persons at increased risk by virtue of their age, risk factors (e.g., pregnancy, tobacco and alcohol use), state of periodontal health, rate of accumulation of tartar, personal oral hygiene practices, and medical and dental history (e.g., diabetes mellitus, xerostomia, HIV infection).

## Effectiveness of Counseling

Survey data suggest that many patients, especially persons in minority groups or those of low socioeconomic status, lack adequate knowledge about how to prevent oral diseases.^ 85 ^ There is little information on the effectiveness of physician advice in changing oral hygiene or dietary habits, increasing the optimal use of fluoride supplements, or increasing patient visits to dentists. Studies of patient education involving dentists, dental hygienists, dietitians, physicians, and other providers have reported mixed results in changing personal oral health practices and suffer from numerous design problems.^86-88^ It is well known among oral health professionals that patients frequently face difficulties in complying with guidelines for proper tooth brushing and dental flossing without repeated reinforcement. Studies suggest that compliance with oral hygiene instruction is often poor.^ 89 ^ There is little information regarding the willingness or ability of patients to comply with clinicians' advice to visit their dental care provider on a regular basis. The effectiveness of counseling to promote a healthy diet is discussed in Chapter 56.

In communities with inadequate water fluoridation, primary care physicians are an important source of supplemental fluoride drops or tablets to prevent dental caries in children. There is little information on patient compliance with such prescriptions. Studies have shown, however, that clinicians often fail to prescribe dietary fluoride supplements in accordance with existing guidelines^ 90 ^ or to determine the fluoride content of the local water supply before doing so.^ 91 ^

## Recommendations of Other Groups

The Canadian Task Force on the Periodic Health Examination recommends water fluoridation, fluoride supplementation in low-fluoride areas, professional topical fluoride and self-administered fluoride mouth rinses for persons with active decay or specific risk factors, and use of fluoride dentifrices. It found insufficient evidence to recommend for or against toothbrushing and flossing, traditional prophylaxis prior to a topical fluoride application or given at a dental recall visit, and dietary counseling of the general population about cariogenic foods.^ 92 ^ The American Dental Association (ADA) advises that the frequency of dental examinations be tailored to the individual.^ 93 ^ The ADA and American Academy of Pediatrics (AAP) have issued new guidelines on the prescription of dietary fluoride supplements for children in areas with inadequate water fluoridation (see below).^94,95^ The AAP^ 96 ^ and other organizations have also issued guidelines on the prevention of early childhood caries (baby bottle tooth decay).

## Discussion

Although there is little scientific evidence that clinician counseling can reduce the incidence of dental diseases such as caries and periodontal disease, it is reasonable to provide patients with information about methods to reduce the risk of developing these potentially painful and disfiguring conditions. There is sufficient evidence of benefit to justify efforts by physicians and other health care professionals to encourage frequent tooth brushing, daily dental flossing, appropriate use of fluorides and certain mouth rinses, healthful diet, and periodic visits to the dental care provider. There is, however, little evidence that this form of counseling must be performed frequently, or that annual or semiannual dental checkups are necessary for persons without clinical evidence of dental disease. Although it is likely that decreased or less frequent consumption of foods containing refined sugars or avoiding between-meal sweets will reduce the incidence of dental caries, this has not been demonstrated recently in a controlled prospective study involving humans (see Chapter 56 for information about the effectiveness of other forms of counseling to promote a healthy diet). Finally, clinicians can offer advice regarding effective measures to reduce the risk of developing oral cancer (see Chapter 16), such as discontinuing the use of tobacco products (see Chapter 54) and reducing the consumption of alcoholic beverages (see Chapter 52).

CLINICAL INTERVENTION

Counseling patients to visit a dental care provider on a regular basis is recommended based on evidence for risk reduction from such visits when combined with regular personal oral hygiene ("B" recommendation) the effectiveness of advising patients to visit a dental care provider has not been evaluated ("C" recommendation). There is little evidence regarding the optimal frequency of visits this recommendation should be made by the patient's dental care provider. Counseling all patients to brush their teeth daily with a fluoride-containing toothpaste and to clean thoroughly between their teeth with dental floss each day is recommended based on the proven efficacy of risk reduction from doing so ("B" recommendation) the effectiveness of clinician counseling to encourage these behaviors has not been adequately evaluated ("C" recommendation). Parents of small children should be encouraged to perform or supervise their children's brushing and to monitor the amount of toothpaste used wiping the teeth with a piece of gauze or damp cloth is typically recommended for cleaning the teeth of children who are too young to use a toothbrush. Parents of infants and young children should be encouraged to breastfeed (see Chapter 56). Providing advice to parents to put infants and children to bed without a bottle may reduce the risk of baby bottle tooth decay ("B" recommendation). See Chapter 56 for other recommendations regarding counseling to promote a healthy diet.

Clinicians caring for children should ascertain the fluoride concentration of their water supply. For children living in an area with inadequate water fluoridation (<0.6 parts per million [ppm]), the prescription of daily fluoride drops or tablets is recommended ("A" recommendation). According to recently revised guidelines,^94,95^ in communities with a water fluoride concentration of less than 0.3 ppm, the recommended dose is 0.25 mg/day for children 6 months to 3 years of age, 0.50 mg/day for children aged 3-6, and 1.0 mg/day for children aged 6-16. In areas with a water fluoride level of 0.3-0.6 ppm, fluoride supplementation is not recommended for children 6 months to 3 years of age. For older children, the recommended dose is 0.25 mg/day for children aged 3-6 and 0.50 mg/day for children aged 6-16. Some groups have issued more conservative recommendations that limit fluoride supplementation to children age 3 and older living in communities with water fluoride concentrations of less than 0.3 ppm.^ 97 ^

When examining the oral cavity, clinicians should be alert for obvious signs of untreated tooth decay or mottling, inflamed or cyanotic gingiva, loose teeth, and severe halitosis, and for signs and symptoms of oral cancer or premalignancy in persons who use tobacco or excessive amounts of alcohol (see Chapter 16). All patients should be counseled to avoid the use of tobacco products (see Chapter 54). When examining children, clinicians should be alert for evidence of early childhood caries (baby bottle tooth decay), mismatching of upper and lower dental arches, crowding or malalignment of the teeth, premature loss of primary posterior teeth (baby molars), and obvious mouth breathing. Patients with these or other suspected abnormalities should be referred to appropriate specialists for further evaluation.

The draft update of this chapter was prepared for the U.S. Preventive Services Task Force by Steven H. Woolf, MD, MPH, with contributions from materials prepared for the Canadian Task Force on the Periodic Health Examination by Amid I. Ismail, BDS, MPH, DrPH, Donald W. Lewis, DDS, DDPH, MScD, FRCDC, and Jennifer L. Dingle, MBA.

## REFERENCES, 61. Dental and Periodontal Disease

1 Public Health Service. Oral health of United States children: the national survey of dental caries in U.S.school children: 1986-1987. National and regional findings. Bethesda: National Institutes of Health. 1989.;(NIH Publication no. 89-2247.).
2 National Institute of Dental Research. Oral health of United States adults, the national survey of oral health in U.S.employed adults and seniors: 1985-86. Bethesda: National Institute of Dental Research. 1987.;(NIH Publication no. 87-2868.).
3 Beck JD, Lainson PA, Field HM, et al. Risk factors for various levels of periodontal disease and treatment need in Iowa. Community Dent Oral Epidemiol. 1984;12:17-22. [pmid: 6583037].
4 Oliver RC, Brown LJ, Loe H. An estimate of periodontal treatment needs in the U.S. based on epidemiologic data. J Periodontol. 1989;60:371-380. [pmid: 2778606].
5 Bhat M. Periodontal health of 14-17-year-old U.S. schoolchildren. J Public Health Dent. 1991;51:5-11. [pmid: 2027103].
6 National Center for Health Statistics. Dental services and oral health: United States, 1989. Vital and health statistics; series 10 no 183. Hyattsville, MD. Hyattsville, MD. 1992:4-5.;(PHS Publication no. 93-1511.).
7 Gift HC, Reisine ST, Larach DC. The social impact of dental problems and visits. Am J Public Health. 1992;82:1663-1668. [pmid: 1456343].
8 Lazenby HC, Letsch SW. National health expenditures, 1989. Health Care Financing Rev. 1990;12:1-26.
9 Oral Health Coordinating Committee, Public Health Service. Toward improving the oral health of Americans: an overview of oral health status, resources, and care delivery. Public Health Rep. 1993;108:657-672. [pmid: 8265750].
10 Gift HC, Redford M. Oral health and the quality of life. Clin Geriatr Med. 1992;8:673-683. [pmid: 1504951].
11 Newbrun E. Effectiveness of water fluoridation. J Public Health Dent. 1989;49(Special Issue):279-289. [pmid: 2681730].
12 Lewis DW, Banting DW. Water fluoridation—current effectiveness and dental fluorosis. Community Dent Oral Epidemiol. 1994;22:153-158. [pmid: 8070242].
13 Stamm JW, Banting DW, Imrey PB. Adult root caries: survey of two similar communities with contrasting natural fluoride water levels. J Am Dent Assoc. 1990;120:143-149. [pmid: 2299058].
14 Burt BA, Eklund SA. Dentistry, dental practice, and the community, 4th ed. Philadelphia: WB Saunders. 1992:162-165.
15 Public Health Service. Review of fluoride benefits and risks: report of the ad hoc subcommittee of fluoride of the Committee to Coordinate Environmental and Health Related Programs. Washington, DC: Department of Health and Human Services. 1991.
16 American Dietetic Association. Position of the American Dietetic Association: the impact of fluoride on dental health. J Am Diet Assoc. 1994;94:1428-1431. [pmid: 7963197].
17 Centers for Disease Control. Fluoridation census, 1992. Washington, DC: Department of Health and Human Services. 1993.
18 Changing patterns of fluoride intake: workshop, Chapel Hill, NC, April 23-25, 1991. J Dent Res. 1992;71:1214-1227. [pmid: 1607438].
19 Heifetz SB, Meyers RJ, Kingman A. A comparison of the anticaries effectiveness of daily and weekly rinsing with sodium-fluoride: final results after three years. Pediatr Dent. 1982;4:300-303.
20 Johnson MF. Comparative efficacy of NaF and SMFP dentifrices in caries prevention: a meta-analytic overview. Caries Res. 1993;27:328-336. [pmid: 8402811].
21 Driscoll WS, Nowjack-Raymer R, Selwitz RH, et al. A comparison of the caries-preventive effects of fluoride mouthrinsing, fluoride tablets, and both procedures combined: final results after eight years. J Public Health Dent. 1992;52:111-116. [pmid: 1564689].
22 Nowjack-Raymer RE, Gift HC. Contributing factors to maternal and child oral health. J Public Health Dent. 1990;50:370-378. [pmid: 2286944].
23 Stephen KW, Kay EJ, Tullis JI. Combined fluoride therapies: a 6-year double-blind school-based preventive dentistry study in Inverness, Scotland. Community Dent Oral Epidemiol. 1990;18:244-248. [pmid: 2249406].
24 Mellberg JM, Ripa LW Fluoride dentifricesIn: Mellberg JM, Ripa LW, eds. Fluoride in preventive dentistry: theory and clinical application. , Chicago:Quintessence,1983 215 241 393342
25 Jensen ME, Kohout FJ. The effect of a fluoridated dentifrice on root and coronal caries in an older adult population. J Am Dent Assoc. 1988;117:829-832. [pmid: 3204243].
26 Ismail AI, Brodeur JM, Kavanagh M, et al. Prevalence of dental caries and dental fluorosis in students, 11-17 years of age, in fluoridated and non-fluoridated cities in Quebec. Caries Res. 1990;24:290-297. [pmid: 2276168].
27 Brunelle JA. The prevalence of dental fluorosis in U.S. children. 1987. J Dent Res 1989;68(Special Issue).
28 Woolfolk MW, Faja BW, Bagramian RA. Relation of sources of systemic fluoride to prevalence of dental fluorosis. J Public Health Dent. 1989;49:78-82. [pmid: 2619788].
29 Szpunar SM, Burt BA. Evaluation of appropriate use of dietary fluoride supplements in the US. Community Dent Oral Epidemiol. 1992;20:148-154. [pmid: 1623707].
30 Nourjah P, Horowitz AM, Wagener DK. Factors associated with the use of fluoride supplements and dentifrice by infants and toddlers. J Public Health Dent. 1994;54:47-54. [pmid: 8164191].
31 Osuji OO, Leake JL, et al. Risk factors for dental fluorosis in a fluoridated community. J Dent Res. 1988;67:1488-1492. [pmid: 3198847].
32 Sowers MFR, Clark MK, Jannausch ML, et al. A prospective study of bone mineral content and fracture in communities with differential fluoride exposure. Am J Epidemiol. 1991;133:649-660. [pmid: 2018020].
33 Cooper C, Wickham CAC, Barker DJR, et al. Water fluoridation and hip fracture. JAMA. 1991;266:513-514. [pmid: 2061972].
34 Danielson C, Lyon JL, Egger M, et al. Hip fractures and fluoridation in Utah's elderly population. JAMA. 1992;268:746-748. [pmid: 1640574].
35 Jacobsen SJ, O'Fallon WM, Melton LJ III. Hip fracture incidence before and after the fluoridation of the public water supply, Rochester, Minnesota. Am J Public Health. 1993;83:743-745. [pmid: 8484462].
36 Suarez-Almazor ME, Flowerdew G, Saunders LD, et al. The fluoridation of drinking water and hip fracture hospitalization rates in two Canadian communities. Am J Public Health. 1993;83:689-693. [pmid: 8484450].
37 Gordon SL, Corbin SB. Summary of workshop on drinking water fluoride influence on hip fracture and on bone health. Osteoporosis Int. 1992;286:109-117.
38 Brecx M, MacDonald LL, Legary K, Cheang M, Forgay MGE. Long-term effects of Meridol and chlorhexidine mouthrinses on plaque, gingivitis, staining, and bacterial vitality. J Dent Res. 1993;72:1194-1197. [pmid: 8360362].
39 Olivier M, Brodeur JM, Simard PL. Efficacy of APF treatments without prior toothcleaning targeted to high-risk children. Community Dent Oral Epidemiol. 1992;20:38-42. [pmid: 1547611].
40 Zimmermann A, Flores-de-Jacoby L, Pan P. Gingivitis, plaque accumulation and plaque composition under long-term use of Meridol. J Clin Periodontol. 1993;20:346-351. [pmid: 8501274].
41 Lamster IB, Alfano MC, Seiger MC, et al. The effect of Listerine antiseptic on reduction of existing plaque and gingivitis. Clin Prev Dent. 1983;5.
42 Gordon JM, Lamster IB, Seiger MC. Efficacy of Listerine antiseptic in inhibiting the development of plaque and gingivitis. J Clin Periodontol. 1985;12:697-704. [pmid: 3902908].
43 DePaola LG, Overholser CD, Meiller TF, et al. Chemotherapeutic inhibition of supergingival supragingival dental plaque and gingivitis development. J Clin Periodontol. 1989;16:311-315. [pmid: 2723103].
44 Lang NP, Hotz P, Graff H, et al. Effect of supervised chlorhexidine mouthrinses in children. J Periodont Res. 1982;17:101-111. [pmid: 6211534].
45 Banting D, Bosma M, Bollmer B. Clinical effectiveness of a 0.12% chlorhexidine mouthrinse over two years. J Dent Res. 1989;68:1716-1718.
46 Yates R, Jenkins S, Newcombe R, et al. A 6-month home usage trial of a 1% chlorhexidine toothpaste (I). Effects on plaque, gingivitis, calculus and toothstaining. J Clin Periodontol. 1993;20:130-138. [pmid: 8436632].
47 Svatun B, Saxton CA, Rolla G. Six-month study of the effect of a dentifrice containing zinc citrate and triclosan on plaque, gingival health, and calculus. Scand J Dent Res. 1990;98:301-304. [pmid: 2399425].
48 Cubells AB, Dalman LB, Petrone ME, et al. The effect of a triclosan/copolymer/fluoride dentifrice on plaque formation and gingivitis: a six-month clinical study. J Clin Dent. 1991;2:63-69. [pmid: 1930698].
49 Bolden TE, Zambon JJ, Sowinski J, et al. The clinical effect of a dentifrice containing triclosan and a copolymer in a sodium fluoride/silica base on plaque formation and gingivitis: a six-month clinical study. J Clin Dent. 1992;3:125-131. [pmid: 1306679].
50 Deasy MJ, Singh SM, Rustogi KN, et al. Effect of a dentifrice containing triclosan and a copolymer on plaque formation and gingivitis. Clin Prev Dent. 1991;13:12-19. [pmid: 1813200].
51 Gustafsson BE, Quensel CE, Lanke LS, et al. The Vipeholm dental caries study: the effect of different levels of carbohydrate intake on caries activity in 436 individuals observed for 5 years. Acta Odontol Scand. 1954;11:232-364. [pmid: 13196991].
52 Harris R. Biology of the children of Hopewood House, Bowral, Australia. IV. Observations of dental caries experience extending over five years (1957-1961). J Dent Res. 1963;42:1387-1398. [pmid: 14081962].
53 Burt RA, Eklund SA, Morgan KJ, et al. The effect of diet on the development of dental caries. Final report, contract DE-22438. Bethesda: National Institute of Dental Research. 1987.
54 Rugg-Gunn AJ, Hackett AF, Appleton DR, et al. Relationship between dietary habits and caries increments assessed over two years in 405 English adolescent schoolchildren. Arch Oral Biol. 1984;29:983-992. [pmid: 6598368].
55 Burt BA, Eklund SA, Morgan KJ, et al. The effects of sugar intake and frequency of ingestion on dental caries increment in a three-year longitudinal study. J Dent Res. 1988;67:1422-1429. [pmid: 3053822].
56 Akpata ES, Al-Shammery AR, Saeed HI. Dental caries, sugar consumption and restorative dental care in 12-13-year-old children in Riyadh, Saudi Arabia. Community Dent Oral Epidemiol. 1992;20:343-346. [pmid: 1464229].
57 Frostell G, Birkhed D, Edwardsson S, et al. Effect of partial substitution of invert sugar for sucrose in combination with Duraphat treatment on caries development in preschool children: the Malmo study. Caries Res. 1991;25:304-310. [pmid: 1913770].
58 Holt RD. Foods and drinks at four daily time intervals in a group of young children. Br Dent J. 1991;170:137-143. [pmid: 2007084].
59 Ripa LW. Nursing caries: a comprehensive review. Pediatr Dent. 1988;10:268-282. [pmid: 3078603].
60 Serwint JR, Mungo R, Negrete VF, et al. Child-rearing practices and nursing caries. Pediatrics. 1993;92:233-237. [pmid: 8337022].
61 Roberts GJ, Cleaton-Jones PE, Fatti LP, et al. Patterns of breast and bottle feeding and their association with dental caries in 1- to 4-year-old South African children. 2. A case control study of children with nursing caries. Community Dent Health. 1994;11:38-41. [pmid: 8193983].
62 O'Sullivan DM, Tinanoff N. Social and biological factors contributing to caries of the maxillary anterior teeth. Pediatr Dent. 1993;15:41-44. [pmid: 8233991].
62A Navia JM. Caries prevention in infants and young children: which etiologic factors should we address?. J Public Health Dent. 1994;54:195-196. [pmid: 7799292].
63 Suomi JD, Greene JC, Vermillion JR, et al. The effect of controlled oral hygiene procedures on the progression of periodontal disease in adults: results after third and final year. J Periodontol. 1971;42:152-160. [pmid: 4396693].
64 Horowitz AM, Suomi JD, Peterson JK, et al. Effects of supervised daily dental plaque removal by children after 3 years. Community Dent Oral Epidemiol. 1980;8:171-176. [pmid: 6936116].
65 Lang NP, Cumming BR, Loe H. Toothbrush frequency as it is related to plaque development and gingival health. J Periodontol. 1973;44:398-405.
66 Caton JG, Blieden TM, Lowenguth RA, et al. Comparison between mechanical cleaning and an antimicrobial rinse for the treatment and prevention of interdental gingivitis. J Clin Periodontol. 1993;20:172-178. [pmid: 8450082].
67 Graves RC, Disney JA, Stamm JW. Comparative effectiveness of flossing and brushing in reducing interproximal bleeding. J Periodontol. 1989;50:243-247.
68 Barnes CM, Weatherford TW, Menaker L. A comparison of the Braun Oral-B Plaque Remover (D5) electric and a manual toothbrush in affecting gingivitis. J Clin Dent. 1993;4:48-51. [pmid: 8267871].
69 Stoltze K, Bay L. Comparison of a manual and a new electric toothbrush for controlling plaque and gingivitis. J Clin Periodontol. 1994;21:86-90. [pmid: 8144738].
70 van der Weijden GA, Timmerman MF, Reijerse E, et al. The long-term effect of an oscillating/rotating electric toothbrush on gingivitis: an 8-month clinical study. J Clin Periodontol. 1994;21:139-145. [pmid: 8144734].
71 Helfenstein U, Steiner M. Fluoride varnishes (Duraphat): a meta-analysis. Community Dent Oral Epidemiol. 1994;22:1-5. [pmid: 8143435].
72 Ripa LW. A critique of topical fluoride methods (dentifrices, mouthrinses, operator-, and self-applied gels) in an era of decreased caries and increased fluorosis prevalence. J Public Health Dent. 1991;51:23-41. [pmid: 2027099].
73 Mertz-Fairhurst EJ, Fairhurst CW, Williams JE, et al. A comparative clinical study of two pit and fissure sealants: 7-year results in Augusta, Georgia. J Am Dent Assoc. 1984;109:252-255. [pmid: 6236247].
74 Llodra JC, Bravo M, Delgado-Rodriguez M, et al. Factors influencing the effectiveness of sealants—a meta-analysis. Community Dent Oral Epidemiol. 1993;21:261-268. [pmid: 8222598].
75 Weintraub JA. The effectiveness of pit and fissure sealants. J Public Health. 1989;49(Special Issue):317-330.
76 Axelsson P, Lindhe J. The effect of a preventive program on dental plaque, gingivitis and caries in school children: results after one and two years. J Clin Periodontol. 1974; 1975;1:126-138. [pmid: 4532119].
77 Axelsson P, Lindhe J. The effect of various plaque control measures on gingivitis and caries in school children. Community Dent Oral Epidemiol. 1976;4:232-239. [pmid: 1069613].
78 Agerback N, De Paola PF, Brudevold F. Effects of professional toothcleaning every third week on gingivitis and dental caries in children. Community Dent Oral Epidemiol. 1978;6:40-41. [pmid: 272263].
79 Ashley FP, Sainsbury RH. The effect of a school-based plaque control programme on caries and gingivitis. Br Dent J. 1981;150:41-45. [pmid: 6936036].
80 Badersten A, Egelberg J, Koch G. Effect of monthly prophylaxis on caries and gingivitis in schoolchildren. Community Dent Oral Epidemiol. 1975;3:1-4. [pmid: 1053968].
81 Hamp SE, Lindhe J, Fornell LA, et al. Effect of a field program based on systematic plaque control on caries and gingivitis in schoolchildren after 3 years. Community Dent Oral Epidemiol. 1978;6:17-23. [pmid: 272260].
82 82. Deleted in proof.
83 Loe H, Kleinman DV. Dental plaque control measures and oral hygiene practices. Proceedings from a state-of-the-science workshop. Washington, DC: IRL Press. 1986.
84 Axelsson P, Lindhe J. Effect of controlled oral hygiene procedures on caries and periodontal disease in adults: results after six years. J Clin Periodontol. 1981;8:239-248. [pmid: 6947990].
85 Gift HC, Corbin SB, Nowjack-Raymer RE. Public knowledge of prevention of dental disease. Public Health Rep. 1994;109:397-404. [pmid: 8190863].
86 Brown LF. Research in dental health education and health promotion: a review of the literature. Health Educ Q. 1994;21:83-102. [pmid: 8188495].
87 Horowitz AM. Effective oral health education and promotion programs to prevent dental caries. Int Dent J. 1982; 1983;33:171-181. [pmid: 6575962].
88 Hollund U. Effect of a nutrition education program, "learning by teaching," on adolescents' knowledge and beliefs. Community Dent Oral Epidemiol. 1990;18:61-65. [pmid: 2335063].
89 Weinstein P, Milgrom P, Melnick S, et al. How effective is oral hygiene instruction? Results after 6 and 24 weeks. J Public Health Dent. 1989;49:32-38. [pmid: 2911075].
90 Kuthy RA, McTigue DJ. Fluoride prescription practices of Ohio physicians. J Public Health Dent. 1987;47:172-176. [pmid: 3478487].
91 Levy SM, Rozier RG, Bawden JW. Use of systemic fluoride supplements by North Carolina dentists. J Am Dent Assoc. 1987;114:347-350. [pmid: 3470358].
92 Canadian Task Force on the Periodic Health Examination. Canadian guide to clinical preventive health care. Ottawa: Canada Communication Group. 1994:408-431.
93 American Dental Association. The importance of professional teeth cleaning. Chicago: American Dental Association. 1985.
94 American Academy of Pediatrics. Fluoride supplementation for children: interim policy recommendations. Pediatrics. 1995;95.
95 New fluoride guidelines proposed. 1994;J Am Dent Assoc. 125.
96 American Academy of Pediatrics policy statement: juice in ready-to-use bottles and nursing bottle caries (RE1422). Elk Grove Village, IL. Elk Grove Village, IL. 1978. [pmcid: 411522].
97 Clark DC. Appropriate use of fluorides in the1990s. J Can Dent Assoc. 1993;59:272-279. [pmid: 8453528].