# COUNSELING

54 Counseling to Prevent Tobacco Use

55 Counseling to Promote Physical Activity

56 Counseling to Promote a Healthy Diet

57 Counseling to Prevent Motor Vehicle Injuries

58 Counseling to Prevent Household and Recreational Injuries

59 Counseling to Prevent Youth Violence

60 Counseling to Prevent Low Back Pain

61 Counseling to Prevent Dental and Periodontal Disease

62 Counseling to Prevent HIV Infection and Other Sexually Transmitted Diseases

63 Counseling to Prevent Unintended Pregnancy

64 Counseling to Prevent Gynecologic Cancers